# CLINICAL PREVENTIVE SERVICES WHERE MORE RESEARCH IS NEEDED: PROMOTING MENTAL HEALTH AND WELLNESS FOR ALL AGES AND SPECIFIC HIGH-RISK POPULATIONS

The U.S. Congress has charged the Task Force with identifying gaps in research and recommending priority areas that deserve further examination each year. This includes calling attention to areas where evidence is lacking for populations that are disproportionately affected by health conditions. There are two ways that the USPSTF highlights evidence gaps in its recommendation statements:

- Issuing an “I statement.” The USPSTF issues an “I statement” when the current evidence is lacking, of poor quality, or conflicting. When the evidence is insufficient, the USPSTF is unable to assess the balance of benefits and harms of the preventive service.
- Describing the “Research Needs and Gaps.” In all recommendation statements, the USPSTF points out where gaps in the evidence remain in a section called “Research Needs and Gaps.”

For studies to adequately address gaps in the evidence, researchers need to use methods that are consistent with the USPSTF’s criteria for assessing study quality, validity, and applicability. Studies addressing these gaps should do the following:

- Examine preventive services conducted in the primary care setting or that are referable from primary care
- Compare outcomes for people who do and do not receive the preventive service
- Include populations without recognized signs or symptoms of the condition
- Adopt a rigorous study design appropriate for the question, such as a randomized, controlled trial or a high-quality observational study
- Be free of significant sources of bias, such as high dropout rates among participants, biased assessment of outcomes, or heterogeneity in outcome measures

To develop recommendations that improve the health of people nationwide, the USPSTF needs high-quality evidence about the benefits and harms of the preventive service and about the ways specific population groups are affected. For some preventive services and for certain populations, lack of scientific evidence limits the ability of the Task Force to make recommendations. This is because particular populations are frequently not well represented in health research. Some examples include:

- Specific age groups, including children, adolescents, and older adults
- Racial and ethnic groups historically underrepresented in research and disproportionately affected by health conditions, such as Black, Hispanic/Latino, Native American/Alaska Native, and Asian American and Pacific Islander people
- People who do not identify as heterosexual, with their birth sex, or both
- Individuals disproportionately affected by genetic, environmental, and social risk factors, such as financial strain or lack of access to affordable care

The Task Force is prioritizing topics that are likely to advance health equity and is calling for more research for some preventive services where the lack of scientific evidence limits its ability to make recommendations. In turn, this can help inform future recommendations, improve access to and use of preventive services, reduce disparities in healthcare, and increase health equity.

## Focusing on Promoting Mental Health and Wellness for All Ages and Specific High-Risk Populations

For this 2023 report, the USPSTF calls attention to high-priority research gaps focusing on promoting mental health and wellness for all ages and specific high-risk populations. Mental health is characterized on a continuum of optimal wellbeing to unhealthy illness and includes a person’s emotional, psychological, and social well-being and affects how they think, feel, and act. Mental health conditions are common and affect many Americans and their families. More than 1 in 5 adults in the United States live with a mental illness,^4^ and more than 1 in 5 youth between the ages of 13 and 18 years currently have a seriously debilitating mental illness or will at some point during their life.^5^

Mental health and wellness are important for all ages, from childhood to adolescence and into adulthood, but this is especially true in some high-risk populations. Risk factors, including genetic, biological, and environmental factors, can contribute to mental health disorders. Prevalence rates can also vary based on age, race and ethnicity, sexual orientation, gender identity, and social determinants of health, such as economic and social conditions. Underserved communities often bear a disproportionately high burden of disability resulting from mental health disorders.^6^

Mental health is equally as important as physical health for overall health and well-being. Mental illness can affect an individual’s physical health, placing them at greater risk of chronic health conditions like diabetes and heart disease. Similarly, the presence of chronic conditions can also increase the risk for mental illness.^7^ Promoting mental health and wellness through screening can be an effective strategy for improving overall health outcomes.

The Task Force calls attention to high-priority research gaps related to mental health and wellness, recognizing that mental health needs increased during the COVID-19 pandemic and the disruption in access to primary care and mental health services may have affected the ability to screen for mental health conditions. The USPSTF has several recommendations related to screening for mental health conditions, including anxiety disorders, depression, and suicide risk in children, adolescents, and adults.

Table 2 Key Research Gaps for Clinical Preventive Services—Promoting Mental Health and Wellness in All Ages and Specific High-Risk Populations

USPSTF Recommendation | Gaps Where Research Is Needed
Screening for Depression and Suicide Risk in Children and Adolescents (October 11, 2022) | Studies are needed that provide more information on the following.; Screening for major depressive disorder (MDD):; - More randomized, controlled trials (RCTs) are needed on the benefits and harms of screening for and treatment of MDD in children age 11 years or younger.; - Large, good-quality RCTs are needed to better understand the overarching effects of screening for MDD on long-term health outcomes.; - More research is needed in child and adolescent populations in primary care settings to study the effects of comorbid conditions on screening accuracy, MDD treatment, and benefits and harms.; - More research is needed on novel systems of primary care delivery (such as collaborative care between primary and mental health care and integrated behavioral health) to maximize the benefit that children and adolescents get from screening.; - More research is needed on screening and treatment in populations defined by sex, race and ethnicity, sexual orientation, and gender identity.; Screening for suicide risk:; - More studies are needed on the benefits and harms of screening for suicide risk in children and adolescents in primary care settings.; - More information is needed on the accuracy of screening tests for suicide risk.; - Treatment studies are needed in populations with screen-detected suicide risk, in all age groups.; - Evidence on screening and treatment is lacking in populations defined by sex, race and ethnicity, sexual orientation, and gender identity, such as Native American/Alaska Native youth (who are at increased risk for suicide).
Screening for Anxiety Disorders in Children and Adolescents (October 11, 2022) | Studies are needed that provide more information on the following.; - More RCTs are needed on the direct benefits and harms of screening for anxiety disorders among children and adolescents in primary care settings; - Multiple types of anxiety disorders exist, so future research should clarify the performance of screening instruments designed to identify any anxiety disorder and instruments designed for specific anxiety disorders.; - More research is needed on the effectiveness of treatment of anxiety disorders in younger children.; - More research is needed on the feasibility of using screening tools for anxiety in the primary care setting.; - More evidence is needed in populations defined by sex, race and ethnicity, sexual orientation, and gender identity.
Screening for Depression and Suicide Risk in Adults (June 20, 2023) | Although the evidence is clear that providing depression screening in adults and pregnant and postpartum patients is beneficial, more research is needed to ensure that all patients receive depression screening equitably. Studies are needed that provide more information on the following.; - Studies are needed that show the effect of depression screening and the most accurate screening tools for Black, Hispanic/Latino, Asian American, and Native American/Alaska Native communities and other underrepresented groups (e.g., populations defined by sex, race and ethnicity, sexual orientation, and gender identity).; - Research is needed that identifies barriers to establishing adequate systems of care and how these barriers can be addressed.; - Rigorous examination of how depression screening is being implemented, including the percentage of patients being screened, referred, and treated for depression, as well as patient health outcomes.; More evidence on whether and how screening for suicide risk can improve health outcomes is needed. There are several critical evidence gaps; more research is needed on the following.; - More research is needed to understand the epidemiology of suicide risk and to determine how primary care can improve health outcomes in persons who are at risk for suicide.; - Research is needed that better defines the accuracy of single-item screeners for suicide risk, embedded within broader depression screening instruments.; - Research is needed on the benefits and potential harms of targeted vs. general screening for suicide risk.; - More information is needed on the potential harms of suicide risk interventions.; - Treatment studies are needed in populations with screen-detected suicide risk in all age groups.; - Studies targeting persons at high risk for suicide, such as Native American/Alaska Native and Hispanic/Latino persons or persons with depression, may help determine whether culturally tailored therapies are more effective in these populations.
Screening for Anxiety Disorders in Adults (June 20, 2023) | Studies are needed that provide more information on the following.; - More research is needed on the accuracy of screening tools for anxiety disorders in older adults.; - More research is needed on the effectiveness of anxiety disorder screening and treatment in older adults.; - More information is needed on screening and treatment in populations defined by sex, race and ethnicity, sexual orientation, and gender identity.; - More research is needed, including RCTs, on the direct benefits and harms of screening for anxiety disorders in primary care settings (or similar settings).; - More research is needed that demonstrates diagnostic accuracy of screening tools that are feasible for use in primary care settings, tested among primary care patients or similar populations, using valid reference standards, and determining (and replicating) optimal cutoffs for various anxiety disorders; research is needed to identify optimal screening intervals in all populations.; - More research is needed on the optimal screening tools to be used in pregnant and postpartum people.; - More evidence is needed on the effectiveness of anxiety disorder treatment in pregnant and postpartum people.; - More research is needed on the barriers to establishing adequate systems of care related to anxiety disorders and how these barriers can be addressed.; - Large epidemiological studies are needed to determine and monitor the prevalence of anxiety disorders.

## Depression in Children and Adolescents

Depression is a leading cause of disability in the United States.^4^ U.S. children and adolescents with depression typically have functional impairments in their performance at school or work, as well as in their interactions with their families and peers. Depression can also negatively affect the developmental trajectories of affected youth. Major depressive disorder (MDD) in children and adolescents is strongly associated with recurrent depression in adulthood; other mental disorders; and increased risk for suicidal ideation, suicide attempts, and suicide completion.^8,9^

The USPSTF identified high-priority gaps related to screening for depression in children and adolescents. To fill these gaps, the USPSTF needs well-designed research that:

- Includes randomized, controlled trials (RCTs) on the benefits and harms of screening for and treatment of MDD in children age 11 years or younger.
- Includes large, good-quality RCTs to better understand the overarching effects of screening for MDD on long-term health outcomes.
- Includes child and adolescent populations in primary care settings to study the effects of comorbid conditions on screening accuracy, MDD treatment, and benefits and harms.
- Studies novel systems of primary care delivery (such as collaborative care between primary and mental health care and integrated behavioral health) to maximize the benefit that children and adolescents get from screening.
- Studies screening and treatment in populations defined by sex, race and ethnicity, sexual orientation, and gender identity.

## Suicide Risk in Children and Adolescents

Suicide is the second leading cause of death among youth ages 10 to 19 years.^10^ Psychiatric disorders and previous suicide attempts increase suicide risk. Rates of suicide attempts and deaths vary by sex, gender, age, and race and ethnicity.^8,9^ The USPSTF identified high-priority gaps related to screening specifically for suicide risk in children and adolescents. To fill these gaps, the USPSTF needs well-designed research that:

- Includes the benefits and harms of screening for suicide risk in children and adolescents in primary care settings.
- Includes the accuracy of screening tests for suicide risk.
- Includes treatment studies in populations with screen-detected suicide risk, in all age groups.
- Includes evidence on screening and treatment in populations defined by sex, race and ethnicity, sexual orientation, and gender identity, such as Native American/Alaska Native youth (who are at increased risk for suicide).

## Anxiety Disorders in Children and Adolescents

Anxiety disorder, a common mental health condition in the United States, comprises a group of related conditions characterized by excessive fear or worry that presents as emotional and physical symptoms.^8,9,11^ The 2018–2019 National Survey of Children’s Health found that 7.8% of children and adolescents ages 3 to 17 years had a current anxiety disorder.^2^ Anxiety disorders in childhood and adolescence are associated with an increased likelihood of a future anxiety disorder or depression.^8,9,11^

The USPSTF identified high-priority gaps related to screening for anxiety disorders in children and adolescents. To fill these gaps, the USPSTF needs well-designed research that includes:

- RCTs on the direct benefits and harms of screening for anxiety disorders among children and adolescents in primary care settings.
- Evaluations of the performance of screening instruments designed to identify any anxiety disorder and instruments designed for specific anxiety disorders, given the multiple types of anxiety disorders.
- The effectiveness of treatment of anxiety disorders in younger children.
- The feasibility of using screening tools for anxiety in the primary care setting.
- Populations defined by sex, race and ethnicity, sexual orientation, and gender identity.

## Depression in Adults, Including Pregnant and Postpartum People

Major Depressive Disorder (MDD) is a common mental disorder in the United States that can have a substantial impact on an individual’s life^14,15^ If left untreated, MDD can be associated with an increased risk of cardiovascular events, exacerbation of comorbid conditions, or increased mortality.^12,14,15^ In 2019, 7.8% (19.4 million) of adults experienced at least one major depressive episode; 5.3% of adults (13.1 million) experienced a major depressive episode with severe impairment.^6,12^ Depression can be a chronic condition characterized by periods of remission and recurrence, often beginning in adolescence or early adulthood. However, full recovery may occur.^12^

Depression is also common in pregnant and postpartum people and affects both the parent and the infant. Depression during pregnancy increases the risk of preterm birth, low birth weight, or small-for-gestational-age.^16,17^ Postpartum depression may interfere with parent-infant bonding.^7^

The USPSTF identified high-priority gaps related to screening for depression in adults, including pregnant and postpartum people. To fill these gaps, the USPSTF needs well-designed research that:

- Studies the effect of depression screening and the most accurate screening tools for Black, Hispanic/ Latino, Asian American, and Native American/Alaska Native communities and other underrepresented groups (e.g., populations defined by sex, race and ethnicity, sexual orientation, and gender identity).
- Identifies barriers to establishing adequate systems of care and how these barriers can be addressed.
- Rigorously examines how depression screening is being implemented, including the percentage of patients being screened, referred, and treated for depression, as well as patient health outcomes.

## Suicide Risk in Adults

Suicide is the 10th leading cause of death in adults (45,390 deaths [2017 data]).^18^ From 2001 to 2017, there was a 31% increase in suicide deaths.^18^ Over the last decade, there has been an 88% rate increase.^19^ In 2020, estimated provisional suicide deaths numbered 45,855, which was 3% less than in 2019 (47,511 deaths).^20,21^ Rates of suicide attempts and deaths vary by sex, age, and race and ethnicity.^2^ Psychiatric disorders and previous suicide attempts increase the risk of suicide.^12^ The USPSTF identified high-priority gaps related to screening specifically for suicide risk in adults, including pregnant and postpartum people.

There are several critical evidence gaps; more research is needed that:

- Helps understand the epidemiology of suicide risk and to determine how primary care can improve health outcomes in persons who are at risk for suicide.
- Better defines the accuracy of single-item screeners for suicide risk, embedded within broader depression screening instruments.
- Includes the benefits and potential harms of targeted vs. general screening for suicide risk.
- Includes the potential harms of suicide risk interventions.
- Includes treatment studies in populations with screen-detected suicide risk in all age groups.
- Includes studies targeting persons at high risk for suicide, such as Native American/Alaska Native and Hispanic/Latino persons or persons with depression, which may help determine the effectiveness of culturally tailored therapies in these populations.

## Anxiety Disorders in Adults, Including Pregnant and Postpartum People

Anxiety disorders are commonly occurring mental health conditions. Anxiety disorders include generalized anxiety disorder, social anxiety disorder, panic disorder, separation anxiety disorder, phobias, selective mutism, and anxiety disorders not otherwise specified.^12^ Anxiety disorders are often unrecognized in primary care settings, and years-long delays in treatment initiation occur.^12,22–24^ Anxiety can be a chronic condition characterized by periods of remission and recurrence. However, full recovery may occur.^12,25^

According to U.S. data collected from 2001 to 2002, the lifetime prevalence of anxiety disorders in adults was 26.4% for men and 40.4% for women.^26^ Generalized anxiety disorder has an estimated prevalence of 8.5% to 10.5% during pregnancy and 4.4% to 10.8% postpartum.^24^ The natural history of anxiety disorders typically begins in childhood and early adulthood, and symptoms appear to decline with age. The USPSTF identified high-priority gaps related to screening for anxiety disorders in adults, including pregnant and postpartum people. To fill these gaps, the USPSTF needs well-designed research that includes:

- Accuracy of screening tools for anxiety disorders in older adults.
- Effectiveness of anxiety disorder screening and treatment in older adults.
- Screening and treatment in populations defined by sex, race and ethnicity, sexual orientation, and gender identity.
- Randomized controlled trials on the direct benefits and harms of screening for anxiety disorders in primary care settings (or similar settings).
- Diagnostic accuracy of screening tools that are feasible for use in primary care settings, tested among primary care patients or similar populations, using valid reference standards, and determining (and replicating) optimal cutoffs for various anxiety disorders; research is needed to identify optimal screening intervals in all populations.
- Accuracy of screening tools to be used in pregnant and postpartum people.
- Effectiveness of anxiety disorder treatment in pregnant and postpartum people.
- Barriers to establishing adequate systems of care related to anxiety disorders and how these barriers can be addressed.
- Large epidemiological studies to determine and monitor the prevalence of anxiety disorders.