# Introduction

The U.S. Preventive Services Task Force (USPSTF or Task Force) is an independent, volunteer group of national experts in prevention, primary care, and evidence-based medicine. Since its inception in 1984, the Task Force has made evidence-based recommendations about clinical preventive services that can be delivered or referred from primary care to improve the health of people nationwide (e.g., by improving quality of life and prolonging life). These recommendations include screening tests, behavioral counseling, and preventive medications.

The mission of the USPSTF is to improve the health of people nationwide by making evidence-based recommendations about clinical preventive services.

The purpose of this report is to update Congress and the research community about high-priority evidence gaps in clinical preventive services identified by the Task Force in 2022 and 2023 related to promoting mental health and wellness for all ages and high-risk populations.