# Appendix E Prior Annual Reports to Congress on High-Priority Evidence Gaps for Clinical Preventive Services (2011-2022)

The table below lists the prior annual Reports to Congress on High-Priority Evidence Gaps for Clinical Preventive Services. Electronic versions of each report are available on the USPSTF website at https://www.uspreventiveservicestaskforce.org/uspstf/about-uspstf/reports-congress.

Year | Title | Theme
2022 | Twelfth Annual Report to Congress on High-Priority Evidence Gaps for Clinical Preventive Services | Recent evidence gaps related to promoting healthy behaviors across the lifespan
2021 | Eleventh Annual Report to Congress on High-Priority Evidence Gaps for Clinical Preventive Services | Health equity in cardiovascular disease and cancer prevention
2020 | Tenth Annual Report to Congress on High-Priority Evidence Gaps for Clinical Preventive Services | Child and adolescent health and health inequities
2019 | Ninth Annual Report to Congress on High-Priority Evidence Gaps for Clinical Preventive Services | Mental health, substance use, and violence prevention
2018 | Eighth Annual Report to Congress on High-Priority Evidence Gaps for Clinical Preventive Services | Cancer prevention and cardiovascular health
2017 | Seventh Annual Report to Congress on High-Priority Evidence Gaps for Clinical Preventive Services | Recent evidence gaps
2016 | Sixth Annual Report to Congress on High-Priority Evidence Gaps for Clinical Preventive Services | Recent evidence gaps
2015 | Fifth Annual Report to Congress on High-Priority Evidence Gaps for Clinical Preventive Services | Women’s health
2014 | Fourth Annual Report to Congress on High-Priority Evidence Gaps for Clinical Preventive Services | Child and adolescent health
2013 | Third Annual Report to Congress on High-Priority Evidence Gaps for Clinical Preventive Services | Older adult health
2012 | Second Annual Report to Congress on High-Priority Evidence Gaps for Clinical Preventive Services | Recent evidence gaps
2011 | First Annual Report to Congress on High-Priority Evidence Gaps for Clinical Preventive Services | Recent evidence gaps