# Appendix D USPSTF Final Recommendations Published October 2022-September 2023

Over the past year, the members of the Task Force continued working on a full portfolio of topics. It published 13 final recommendation statements with 19 recommendation grades in a peer-reviewed journal between October 1, 2022, and September 30, 2023. For a complete listing of all current USPSTF recommendations, see the USPSTF website (https://www.uspreventiveservicestaskforce.org/).

Topic | Recommendation
Folic Acid Supplementation to Prevent Neural Tube Defects | The USPSTF recommends that all persons planning to or who could become pregnant take a daily supplement containing 0.4 to 0.8 mg (400 to 800 μg) of folic acid. (Grade A)
Hormone Therapy for the Primary Prevention of Chronic Conditions in Postmenopausal Persons | The USPSTF recommends against the use of combined estrogen and progestin for the primary prevention of chronic conditions in postmenopausal persons. (Grade D); The USPSTF recommends against the use of estrogen alone for the primary prevention of chronic conditions in postmenopausal persons who have had a hysterectomy. (Grade D)
Preexposure Prophylaxis to Prevent Acquisition of HIV | The USPSTF recommends that clinicians prescribe preexposure prophylaxis with effective antiretroviral therapy to persons who are at increased risk of HIV acquisition to decrease the risk of acquiring HIV. (Grade A)
Screening for Anxiety in Children and Adolescents | The USPSTF recommends screening for anxiety in children and adolescents ages 8 to 18 years. (Grade B); The USPSTF concludes that the current evidence is insufficient to assess the balance of benefits and harms of screening for anxiety in children age 7 years or younger. (I statement)
Screening for Anxiety Disorders in Adults | The USPSTF recommends screening for anxiety disorders in adults, including pregnant and postpartum persons. (Grade B); The USPSTF concludes that the current evidence is insufficient to assess the balance of benefits and harms of screening for anxiety disorders in older adults. (I statement)
Screening for Depression and Suicide Risk in Children and Adolescents | The USPSTF recommends screening for major depressive disorder (MDD) in adolescents ages 12 to 18 years. (Grade B); The USPSTF concludes that the current evidence is insufficient to assess the balance of benefits and harms of screening for MDD in children age 11 years or younger. (I statement); The USPSTF concludes that the current evidence is insufficient to assess the balance of benefits and harms of screening for suicide risk in children and adolescents. (I statement)
Screening for Depression and Suicide Risk in Adults | The USPSTF recommends screening for depression in the adult population, including pregnant and postpartum persons, as well as older adults. (Grade B); The USPSTF concludes that the current evidence is insufficient to assess the balance of benefits and harms of screening for suicide risk in the adult population, including pregnant and postpartum persons, as well as older adults. (I statement)
Screening for Latent Tuberculosis Infection in Adults | The USPSTF recommends screening for latent tuberculosis infection in populations at increased risk. (Grade B)
Screening for Lipid Disorders in Children and Adolescents | The USPSTF concludes that the current evidence is insufficient to assess the balance of benefits and harms of screening for lipid disorders in children and adolescents age 20 years or younger. (I statement)
Screening for Hypertensive Disorders of Pregnancy | The USPSTF recommends screening for hypertensive disorders in pregnant persons with blood pressure measurements throughout pregnancy. (Grade B)
Screening for Obstructive Sleep Apnea in Adults | The USPSTF concludes that the current evidence is insufficient to assess the balance of benefits and harms of screening for obstructive sleep apnea in the general adult population. (I statement)
Screening for Skin Cancer | The USPSTF concludes that the current evidence is insufficient to assess the balance of benefits and harms of visual skin examination by a clinician to screen for skin cancer in adolescents and adults. (I statement)
Serologic Screening for Genital Herpes Infection | The USPSTF recommends against routine serologic screening for genital herpes simplex virus infection in asymptomatic adolescents and adults, including pregnant persons. (Grade D)