# Appendix C Federal Liaisons to the USPSTF

- Centers for Disease Control and Prevention
- Centers for Medicare & Medicaid Services
- Department of Defense Military Health System
- Department of Health and Human Services, Office of Minority Health
- Department of Veterans Affairs National Center for Health Promotion and Disease Prevention
- Health Resources and Services Administration
- Indian Health Service
- National Cancer Institute
- National Institutes of Health
- Office of the Assistant Secretary for Health, Office of Disease Prevention and Health Promotion
- Substance Abuse and Mental Health Services Administration
- U.S. Food and Drug Administration

“The Office of Disease Prevention coordinates and promotes prevention research at the National Institutes of Health (NIH) in concert with NIH’s Institutes and Centers. When the USPSTF issues its recommendations and identifies gaps in the evidence base on specific topics, the NIH responds. We support the USPSTF’s commitment to highlighting important evidence gaps in mental health, particularly for those at increased risk, and we are focused on advancing research opportunities and making investments that prioritize closing these gaps.”

David M. Murray, Ph.D.

Associate Director for Prevention

Director, Office of Disease Prevention

National Institutes of Health

“SAMHSA works every day to improve the lives of individuals living with mental health and substance use disorders. With the Nation facing a mental health crisis, this work is as important as it has ever been. By identifying the critical gaps in the evidence—especially among those at high risk—the USPSTF is helping to shape future research that will ultimately provide evidence-based guidance on how to support mental health at every stage of life. We join the USPSTF’s call for more research so that people of all ages and backgrounds can live long, healthy lives.”

Miriam E. Delphin-Rittmon, Ph.D.

Assistant Secretary for Mental Health and Substance Use

Substance Abuse and Mental Health Services Administration