# Appendix B USPSTF Dissemination and Implementation Partner Organizations

- AARP
- American Academy of Family Physicians
- American Academy of Pediatrics
- American Academy of Physician Associates
- American Association of Nurse Practitioners
- American College of Nurse-Midwives
- American College of Obstetricians and Gynecologists
- American College of Physicians
- American College of Preventive Medicine
- American Geriatrics Society
- American Medical Association
- American Osteopathic Association
- American Psychological Association
- America’s Health Insurance Plans
- Association of American Indian Physicians
- Business Group on Health
- Canadian Task Force on Preventive Health Care
- Community Preventive Services Task Force
- GLMA: Health Professionals Advancing LGBTQ+ Equality
- National Association of Pediatric Nurse Practitioners
- National Committee for Quality Assurance
- National Council of Asian Pacific Islander Physicians
- National Hispanic Medical Association
- National Medical Association/Cobb Institute
- Patient-Centered Outcomes Research Institute

## Partnership With GLMA: Reaching LGBTQ+ Communities

Individuals in the LGBTQ+ community are at higher risk for experiencing mental health conditions.

- LGBTQ+ individuals are more than twice as likely as heterosexual men and women to have a mental health disorder.^i^
- LGBTQ+ youth are more than four times as likely to attempt suicide than their peers.^ii^
- Every 45 seconds one LGBTQ+ youth (13–24) attempts suicide. ^iii^

GLMA: Health Professionals Advancing LGBTQ+ Equality is helping confront this problem. For more than 40 years ago, GLMA has ensured health equity for lesbian, gay, bisexual, transgender, and queer (LGBTQ+) people, and equality for LGBTQ+ health professionals in their work and learning environments. GLMA does so by utilizing the scientific expertise of its diverse members to inform and drive advocacy, education, and research.

### Promoting LGBTQ+ Research

There is a vital need for more LGBTQ+ specific research. The existing body of evidence is underfunded and underpowered to understand the unique needs of the LGBTQ+ population. It is crucial that future research be more representative of LGBTQ+ communities to better deliver care to this population and meet their specific health needs. GLMA is urgently calling for more research in this area and promoting LGBTQ+ research by:

- Working with researchers to recruit LGBTQ+ individuals to participate in their research studies.
- Providing guidance on how to make research projects designed around LGBTQ+ communities more inclusive.
- Stewarding the Lesbian Health Fund, which helps to improve the health and well-being of LGBTQ+ women and girls through funding scientific research.

### Providing Healthcare Professionals With Knowledge to Provide Care

To achieve greater benefits of screening it’s essential to address the growing need for healthcare professionals that can provide high quality and culturally competent care to LGBTQ+ patients. GLMA helps to do this by providing access to a variety of educational resources including continuing medical education courses, webinars, conferences, and other resources on LGBTQ+ health. GLMA also offers health professional trainings about the issues facing the LGBTQ+ community to support them in discussing these issues with their patients and others.

### Partnering With the Task Force

The partnership between GLMA and the Task Force provides healthcare professionals with evidence-based and comprehensive guidance on mental health, such as the new recommendations on screening for anxiety disorders, and other conditions that affect LGBTQ+ communities to enhance the health, wellness, and quality of life of their patients.

## Partnership With the American Psychological Association: A Focus on Mental Health

### About the American Psychological Association (APA)

Founded in 1892, the APA:

- Serves as the leading scientific and professional organization representing psychology in the United States.
- Represents more than 146,000 researchers, educators, clinicians, consultants, and students.

The APA works to advance psychology to benefit society and improve lives. By working with the USPSTF, the APA helps to promote positive mental health in the broader population.

### Confronting the Demand for Mental Health Practitioners

In the past few years, the demand for mental health services has skyrocketed. The APA is addressing this challenge by:

- Expanding the number of clinical internship training programs.
- Encouraging people of all races, ethnicities, and other diverse backgrounds to enter doctoral psychology programs to diversify those in the pipeline.
- Increasing the number of professionals who can work in psychology by providing an accreditation process for programs that offer master’s degree in psychology.

### Addressing the Health of the Entire Population

The APA is broadening its approach to promoting mental well being and reaching and treating people with mental health conditions. APA encourages psychologists to adopt a population health approach to their work, which focuses on improving the health of entire populations, including individuals within those populations. Using this approach when providing care to patients, healthcare professionals would take into account factors that influence health status, such as income, education, culture, and environment to reduce risk and prevent problems across populations. Implementing a population health approach will help to improve the health of more people and reduce health inequities.

### Partnering With the Task Force

Through its partnership with the Task Force, APA raises awareness of mental health conditions and emphasizes the importance of integrating mental health within primary care. Task Force recommendations can also serve as a resource for healthcare professionals to use when starting the conversation about mental health with their patients.

“Since 1930, the American Academy of Pediatrics has been committed to attaining optimal physical, mental, and social health and well-being for all children. While evidence-based guidance is essential to providing high quality and comprehensive care, there are often gaps in the evidence, particularly among children and teens. We applaud the USPSTF for focusing this year’s report on the critical research gaps related to anxiety, depression, and suicide risk, especially among those who are underserved and at higher risk. We hope future research will address these gaps, including the role of childhood experiences and relationships in the evolution of mental health problems and substance use disorders, and how those caring for children can effectively intervene, so we have the knowledge we need to keep every child healthy.”

Sandy L. Chung, M.D., FAAP

President

American Academy of Pediatrics

i American Psychiatric Association. Diversity & Health Equity Education: Lesbian, Gay, Bisexual, Transgender and Queer/Questioning. https://www.psychiatry.org/psychiatrists/diversity/education/lgbtq-patients

ii The Trevor Project (2021) Facts About LGBTQ Youth Suicide. https://www.thetrevorproject.org/resources/article/facts-about-lgbtq-youth-suicide/

iii The Trevor Project (2021) Facts About LGBTQ Youth Suicide. https://www.thetrevorproject.org/resources/article/facts-about-lgbtq-youth-suicide/