# Appendix A Members of the USPSTF (2023)

Michael J. Barry, M.D., Chair

Dr. Barry is the director of the Informed Medical Decisions Program in the Health Decision Sciences Center at Massachusetts General Hospital. He is also a professor of medicine at Harvard Medical School and a primary care clinician at Massachusetts General Hospital.

Wanda K. Nicholson, M.D., M.P.H., M.B.A., Vice Chair

Dr. Nicholson is a senior associate dean for diversity, equity, and inclusion and professor of prevention and community health at the Milken Institute School of Public Health at the George Washington University. She is a member and vice-president-elect of the board of directors of the American Board of Obstetrics & Gynecology; editor for health equity, diversity, and inclusion for the American Journal of Obstetrics & Gynecology; past chair of the American College of Obstetricians and Gynecologists (ACOG) Diversity, Equity, and Inclusive Excellence Workgroup; and an immediate past member of the executive board of ACOG.

Michael Silverstein, M.D., M.P.H., Vice Chair

Dr. Silverstein is the George Hazard Crooker University professor of health services, policy, and practice at the Brown University School of Public Health and the director of Brown University’s Hassenfeld Child Health Innovation Institute, which is charged with eliminating health inequities in pregnancy and childhood for Rhode Island families.

David Chelmow, M.D., Member

Dr. Chelmow is the Leo J. Dunn professor of obstetrics and gynecology and chair of the department of obstetrics and gynecology at Virginia Commonwealth University School of Medicine in Richmond, Virginia. He has been chair of the department since 2010 and recently completed service as interim dean for the School of Medicine.

Tumaini Rucker Coker, M.D., M.B.A., Member

Dr. Coker is division head of General Pediatrics and professor of pediatrics at the University of Washington School of Medicine and Seattle Children’s. She serves as the co-director of the University of Washington’s Child Health Equity Research Fellowship, which is funded by the National Institutes of Health.

Esa M. Davis, M.D., M.P.H., Member

Dr. Davis is a professor of medicine and family and community medicine, the associate vice president for community health, and the senior associate dean of population and community medicine at the University of Maryland School of Medicine. She is the lead health equity strategist for the University of Maryland Institute for Health Computing. Dr. Davis is also the director of the Transforming Biomedical Research and Academic Faculty Through Leadership Opportunities, Training, and Mentorship (TRANSFORM) program.

Katrina Donahue, M.D., M.P.H., Member

Dr. Donahue is a professor and vice chair of research at the University of North Carolina at Chapel Hill Department of Family Medicine. She is a family physician and senior research fellow at the Cecil G. Sheps Center for Health Services Research and the co-director of the North Carolina Network Consortium, a meta-network of six practice-based research networks and four academic institutions in North Carolina.

Li Li, M.D., Ph.D., M.P.H., Member

Dr. Li is a family physician and the Walter M. Seward professor and the chair of family medicine at the University of Virginia (UVA) School of Medicine. He is also the director of population health at UVA Health and leader of the Cancer Prevention and Population Health program at the UVA Comprehensive Cancer Center.

Gbenga Ogedegbe, M.D., M.P.H., Member

Dr. Ogedegbe is the founding director of the Institute for Excellence in Health Equity at NYU Langone Health. He is the Dr. Adolph and Margaret Berger professor of medicine and population health at NYU Grossman School of Medicine. Dr. Ogedegbe is a member of the National Academy of Medicine.

Goutham Rao, M.D., FAHA, Member

Dr. Rao is the chair of the Department of Family Medicine and Community Health and chief clinician experience officer for the University Hospitals Health System. He practices family medicine and leads the medical obesity treatment program. He also serves as division chief of Family Medicine at UH Rainbow Babies & Children’s Hospital. In addition, Dr. Rao is the Jack H. Medalie professor and chair of the Department of Family Medicine and Community Health at Case Western Reserve University School of Medicine.

John M. Ruiz, Ph.D., Member

Dr. Ruiz is a professor of clinical psychology in the Department of Psychology at the University of Arizona, where he is also director of diversity, equity, and inclusivity.

James Stevermer, M.D., M.S.P.H., Member

Dr. Stevermer is the vice chair for clinical affairs and Paul Revare, MD, professor of family and community medicine at the University of Missouri (MU). He is the medical director of MU Health Care Family Medicine–Callaway Physicians, where he practices and teaches rural primary care. His scholarly activities focus on dissemination and evidence-based medicine.

Joel Tsevat, M.D., M.P.H., Member

Dr. Tsevat is a general internist, professor of medicine, and Joaquin G. Cigarroa, Jr., M.D., distinguished chair in the Joe R. and Teresa Lozano Long School of Medicine at The University of Texas Health Science Center at San Antonio.

Sandra Millon Underwood, R.N., Ph.D., Member

Dr. Underwood is a professor emerita in the College of Nursing at the University of Wisconsin-Milwaukee. She is a nurse researcher, educator, and clinician with 40 years of experience in the design, implementation, and evaluation of evidence-based programs that aim to foster diversity, inclusion, and health equity, and improve health outcomes among diverse, underserved, at-risk populations.

John B. Wong, M.D., Member

Dr. Wong is vice chair for academic affairs, chief of the Division of Clinical Decision Making, and a primary care clinician in the Department of Medicine at Tufts Medical Center. He is also a professor of medicine at Tufts University School of Medicine.