# Telehealth Education for Asthma Connecting Hospital and Home (TEACHH)

AHRQ Grant Final Progress Report

## PURPOSE

In our application for pilot funding, we initially proposed the following aims:

- Aim 1: Determine the feasibility and acceptability of implementing the Telehealth Education for Asthma Connecting Hospital and Home (TEACHH) intervention for children with asthma throughout the hospital-to-home transition.
- Aim 2: Estimate the preliminary efficacy of TEACHH on patient-important outcomes, and provide parameter estimates for a subsequent full-scale trial. Planned key outcomes included total asthma-related hospital and ED visits within 6-months of discharge, symptom-free days reported by caregivers follow-up assessments, and caregiver asthma-related quality of life.

Shortly after the Agency for Healthcare Research and Quality awarded this R03, the PI was selected to receive a Catalyst Award from the American Lung Association (ALA). Our team recognized that the quantitative methods proposed for the R03 would be unable to capture unique stakeholder insights about TEACHH, or identify ways in which the intervention might be revised to better meet the asthma care needs of hospitalized children and families. The ALA Catalyst Award provided a funding mechanism for conducting a focused qualitative investigation to compliment and extend upon findings from the R03 pilot.

Because the Catalyst Award work was only possible as a result of initial AHRQ funding, we include brief details about the methods and findings of this companion study in our final report. The overall objectives of this combined work were to determine the feasibility of implementing an intervention of health literacy-informed, telemedicine-enhanced asthma education to hospitalized children and caregivers; describe changes in patient-centered asthma outcomes; and assess caregiver and primary care provider perspectives on the intervention.

## SCOPE

### Background and Context

Asthma is the most prevalent chronic disease of childhood, affecting more than 8% of children across the US.^1^ Poorly controlled asthma is a leading driver of pediatric acute care utilization (ACU), including >74,000 hospitalizations and >760,000 emergency department (ED) visits per year.^2,3^ Marked sociodemographic disparities in asthma hospitalization rates have been well described, with the highest burden experienced by children from poor and historically minoritized populations.^4–6^ For example, Black children are >2 times more likely to be hospitalized for asthma than White children.^7^ Children requiring inpatient care are at risk of future asthma-related ACU:^8^ within 6-months of discharge, 40% of children will be readmitted or go to the ED.^9^ While readmissions can reinforce and perpetuate longstanding disparities, most repeat admissions could be prevented with enhancements to the delivery of guideline-based asthma care.^10^

Education to support home management is a pillar of guideline-based asthma care.^11^ Teaching about effective management practices can increase adherence with preventive medicines, reduce morbidity including exacerbations requiring acute healthcare use, and start to reduce disparities.^12,13^ The period during and immediately after a hospital admission represents a critical window for delivering this essential support: not only are these children at greater risk for subsequent exacerbations, but caregivers may also experience greater motivation to change their approach to home management during this vulnerable time.^14^

Unfortunately, barriers to delivering educational support exist across healthcare settings and result in missed opportunities for providing families with needed guidance. First, hospitalizations are stressful for children and families. Caregivers may feel like they are “in a fog,” and forget much of what they have been taught without an opportunity for reinforcement.^15,16^ Second, discharge instructions are often complex, and confusion resulting from these instructions can lead to dosing errors or non-adherence.^17^ Caregivers from poor and historically marginalized populations are at particular risk of misunderstanding discharge instructions,^17^ as low health literacy is more prevalent among these groups.^18^ Many children do not follow-up with a primary care provider (PCP) within 30 days of discharge,^19,20^ and therefore miss an important opportunity for teaching to be reinforced by a trusted healthcare provider. However, even when clinic follow-up does occur, many children with uncontrolled asthma may not receive medication counseling or a written action plan.^21^ Few interventions optimize and sustain preventive asthma care following the hospital-to-home transition. Novel methods are needed to ensure patient-centered support during this critical period.

Teaching that does occur is often not optimized to engage and support children as emerging stakeholders in their care. School-aged children increasingly share responsibility for preventive medication use as they get older.^22^ Prior research has indicated that educational interventions for chronic childhood conditions are most effective when pediatric patients are involved.^12^ Patients want to talk about their medications and are more adherent when involved in such discussions.^23–25^ Yet, children are commonly excluded from clinical conversations about routine management by either caregivers or providers.^26,27^ Furthermore, common tools for presenting information about medications (e.g., written action plans), are often written using language that is less accessible to patients with lower health literacy levels – which may include children.^28^ As a result, children and adolescents grow to develop self-management responsibilities without essential knowledge about their treatment regimen including when to use prescribed therapies.^29^ It is perhaps unsurprising that adherence gradually decreases as children get older.^30^ Low management self-efficacy and inadequate teaching about medications are important barriers to adherence for this group of patients as they gain independence from caregiver oversight.^31,32^ Providers need to support these key stakeholders by providing asthma management information that they can understand and apply.

Importantly, even simplified instructions that include medication names can be difficult for children and parents to follow, since they often use shape or color to identify medications.^29,33,34^ The lack of standardized physical appearances across classes of asthma medications creates further potential for confusion: rescue and controller medications often share the same color, and device colors may change when medicines are refilled or formularies change. Improving adherence for these children will require asthma education that uses both materials appropriate for low health literacy populations and techniques to promote reliable visual identification of prescribed medications.

This pilot study incorporates evidence-based strategies to address longstanding gaps in care and provide asthma support that is truly patient-centered and accessible.

### Setting

This work was completed at the Golisano Children’s Hospital (GCH), a tertiary care children’s hospital in urban Rochester, NY that is part of the University of Rochester Medical Center. With 148 beds, the GCH tower provides care for more than 85,000 children per year including 6,900 inpatient admissions. It is a major referral site for a 17-county Finger Lakes region, and a training site for medical students, residents, and fellows across disciplines.

### Participants/Sample

We enrolled a convenience sample of children 5–13 years old who were hospitalized at GCH with a primary or secondary diagnosis of asthma, and who met clinical definitions for poor control and/or persistent asthma severity over the preceding month per national asthma management guidelines. Eligibility also required a provider decision to discharge the patient home from the hospital with a daily preventive medication, whether prescribed prior to hospitalization or newly initiated. Children and caregivers were excluded if they were unable to speak or understand English, had no phone with which to complete follow-up surveys, no access to a smartphone or other device on which to complete Zoom telehealth follow-up visits, or if the child had a chronic physical or developmental disability that might interfere with either the assessment of recent asthma symptoms and/or the child’s ability to participate in the intervention.

The range of eligible patient ages was informed by several factors: 1) young children suffer the largest burden of preventable asthma morbidity, especially those from poor or historically marginalized patient populations; 2) young children are at high risk for inadequate asthma therapy; 3) some children start to participate in home medication use around age 5 years;22 and 4) adolescents in the mid-teenage years have differing medical and developmental needs compared to younger children, including co-management roles with caregivers that shift toward increasing child independence after age 13 years. The average age for US children to start kindergarten is 5 years. The pictorial lessons, hands-on interactive demonstration technique, and application of stickers to medications described below are developmentally appropriate activities for most children in this age group.

## METHODS

### Study Design

We conducted a pilot randomized trial of the Telehealth Education for Asthma Connecting Hospital and Home (TEACHH) intervention vs. a Standard Care (SC) comparison group. Hospitalized children were systematically screened, and their caregivers approached for enrollment. After enrollment, participants were randomly assigned to TEACHH or SC. We measured feasibility continuously and monitored key outcomes during telephone surveys completed 2-, 4-, and 6-months after enrollment. As part of the companion qualitative research described above, all caregivers were invited to complete an additional in-depth interview to solicit feedback on the TEACHH intervention and better understand family experiences with asthma management, past educational support, and unmet home care needs. To compliment caregiver perspectives, we also interviewed pediatric primary care providers who manage childhood asthma and are expected to resume care for patients following hospitalization.

### Screening

We identified patients who might be eligible through a daily review of the electronic health record (EHR) for children admitted to GCH for asthma-related care. This included admissions to general care wards as well as the pediatric intensive care unit (PICU), provided that the child in the PICU was clinically improving and the PICU provider team approved of approaching the child and family for participation. We then completed a brief screening questionnaire with caregivers at the bedside to confirm eligibility. All caregivers provided written consent, and children ≥7 years old provided verbal assent.

### Baseline Assessment

After obtaining consent/assent, we administered a baseline survey to caregivers at the bedside. This assessment collection information about patient and caregiver demographics, family history, and patient health history variables. We assessed recent asthma symptoms, exposure to secondhand tobacco smoke at home, and caregiver asthma-related quality of life. Questions were drawn from validated survey instruments when available (see ‘Measures,’ below). All questions were read aloud to caregivers.

### Randomization

At the end of the baseline assessment, participants were randomly assigned to either the TEACHH or Standard Care (SC) control groups. Randomization was performed using a permuted block design to ensure an equal balance of children in each group over time. The randomization scheme was developed independently by a biostatistician and implemented electronically via REDCap,™ which was also used for the baseline and follow-up surveys. All families received information on community asthma resources, home environmental triggers, and smoking cessation. A notification of enrollment was mailed to each child’s PCP.

### Standard Care (SC) Comparison Condition

Participants randomized into the SC group received medical treatment from the pediatric hospital medicine or intensive care provider teams in accordance with institutional asthma care protocols. Providers decided if consultations to the pediatric pulmonology team were indicated, and made all determinations about asthma treatment including whether to initiate, continue, or adjust preventive medications. Pre-recorded instructional videos about home asthma care were available and recommended for viewing while hospitalized, though not required. The medical team completed a written asthma action which was reviewed with caregivers by a nurse as part of the discharge paperwork. Finally, all patients received a recommendation to follow-up with their PCP within a week of discharge.

### TEACHH Intervention

All standard care elements were provided to children randomized into the TEACHH group. The TEACHH group also received comprehensive educational support for home asthma management in both inpatient and outpatient settings that was designed to build understanding and skill in medication use.

#### Inpatient Components of TEACHH Intervention

All inpatient teaching activities were completed at the bedside, and included:

1. [underlined: Scripted asthma education]: The educator began teaching both children and caregivers using “Let’s Take Control of Asthma.” This tool, developed by the Asthma Coalition of Queens, NY, provides a brief overview of asthma physiology, triggers, different medications, and written action plans. A flip-chart design presents learners with visual imagery to communicate essential teaching points, while an educator-facing script ensures consistency of teaching.
2. [underlined: A review of medication technique]: The educator shared pictorial instructions for using a metered-dose inhaler (MDI) with a spacer device developed by the Asthma Coalition of Erie County, NY. A printed copy of this single-page pictorial guide was provided to caregivers for referencing at home as needed. Children admitted to GCH because of an asthma exacerbation are typically treated with an albuterol MDI and spacer (instead of nebulizer), unless a higher level of respiratory support is indicated. The educator demonstrated appropriate technique using the child’s own medication when available and permitted by the bedside nurse. A practice inhaler without medication and spacer were available for teaching if needed. Finally, the educator used teach-back methods to confirm understanding among both learners and correct errors in technique as needed.
3. [underlined: A pictorial asthma action plan]: The educator shared and reviewed a pictorial asthma action plan reflecting the home treatment plan. Our team confirmed provider treatment plans before completing the document and requested that prescriptions for home asthma medications be sent to the on-site hospital outpatient pharmacy. Prescriptions filled by this pharmacy during hospitalization can be delivered to inpatient wards for patients to have in hand at the time of discharge. The pictorial action plan was organized according to a traffic light color scheme standard to most written action plans, with information about medications grouped into three sections: 1) a green zone about preventive medicines to be used every day, 2) a yellow zone describing what rescue medication to give when the child is sick, and a brief description of what asthma symptoms might be experienced, and 3) a red zone with instructions for what to do when the child is very sick and not responding to rescue medications. Each zone also featured a color-coded shape (i.e., green star, yellow circle, or red octagon) for later use when labeling medications (see below). This plan was designed using plain language and images of the child’s prescribed medications to improve accessibility for participants with different literacy levels.
4. [underlined: Medication labels]: The educator provided color- and shape-coded stickers intended to distinguish preventive medications (green stars) from rescue medications (yellow and red circles). Using stickers with distinct shapes and colors that matched action plan symbols was intended to ensure that subjects with red-green color blindness could still benefit from the intervention. These stickers were applied to available medications by patients with caregiver assistance, and teach-back methods were used to ensure participant understanding of when to use each medicine. We provided additional labels for families to apply at home to medications that were not available at the bedside, whether during telehealth teaching sessions after discharge or for future refills.
5. The TEACHH intervention used the encrypted, HIPAA-compliant, and free Zoom teleconferencing software for follow-up telehealth education and home management support after discharge. Prior to discharge, the educator offered to help caregivers through the process of downloading and installing the free Zoom app onto a smartphone or other compatible device. No caregivers required such assistance, with all of them citing familiarity with Zoom as a result of the COVID-19 pandemic.

#### Outpatient Components of TEACHH Intervention

Two videoconferencing sessions for follow-up asthma education were completed after discharge, with timing that aligned with guideline-based recommendations for follow-up after hospitalization. Of note, telehealth visits for the delivery of follow-up teaching were intended to supplement (not replace) the PCP follow-up visit recommended for all hospitalized patients following discharge.

1. The first visit (2–4 days after discharge) was designed to review and reinforce essential components of inpatient teaching. The asthma educator used digital versions of the teaching materials first introduced to patients in the hospital, formatted for easy viewing on a smartphone device equipped with the Zoom app. This included a review of “Let’s Take Control of Asthma,” inhaler technique, and the pictorial action plan, with teach-back used to confirm understanding. This visit also included the labeling of any home medications as needed, and a discussion about adherence strategies.
2. The second visit (3 weeks after visit #1) was intended to reinforce previous lessons, with a particular emphasis on the importance of ongoing preventive medication use after an exacerbation has resolved. The educator also reviewed dose counters on an inhaler devices, plans for requesting refills, and how to label any future refills as needed. Checklists were used to ensure that intervention components were delivered as intended.

### Measures

At the time of enrollment, we asked caregivers to share details about the patient and brief information about themselves. These questions included child age, gender, race/ethnicity, insurance coverage, exposure to secondhand smoke at home, and age at initial asthma diagnosis; caregiver education, marital status, and smoking status; and family history of asthma.

We assessed the feasibility of implementing the TEACHH intervention by monitoring the completion of inpatient and virtual education sessions, as well as the time it took for components to be delivered following discharge.

Other key measures included acute healthcare use, recent asthma symptoms, and caregiver asthma-related quality of life. We assessed asthma-related acute healthcare use (i.e., hospitalizations or ED visits) during the 12-months prior to enrollment using EHR data linked across a 13-county area by a regional health information organization. We similarly collected this data for each patient during a 6-month period following enrollment. This approach permitted objective data to be collected on acute visits at either of the two locations for dedicated pediatric emergency and inpatient care in the region (i.e., the University of Rochester Golisano Children’s Hospital or the Rochester General Hospital), regardless of potential attrition. We measured symptom-free days (SFD) by asking caregivers to report the number of 24-hour periods in the previous two weeks during which their child experienced no asthma symptoms, an approach used in several of Dr. Halterman’s previous asthma trials.^35,36^ Finally, we assessed caregiver quality of life during the previous one week using Juniper’s Pediatric Asthma Caregiver Quality of Life (QOL) Questionnaire (score range 1–7 points; higher scores reflect better QOL).^37^ The minimal clinically important difference (MCID) in QOL scores is 0.5 points.

### Outcomes assessment

We followed all subjects for six months. After the baseline assessment, we conducted a series of three telephone-based surveys completed 2-, 4-, and 6-months after enrollment. These surveys were done by a trained research assistant masked to group allocation. Each assessment repeated key measures from baseline. We additionally collected EHR data on asthma-related hospitalizations and ED visits within 6-months of enrollment. Caregivers received $20 on a refillable debit card (Advarra) for every completed assessment ($80 total per family).

We also invited all caregivers in both groups to complete a single 30–45 minute in-depth interview over Zoom (or telephone if needed). These interviews examined prior experiences with learning about asthma, difficulties experienced while managing asthma at home, and perceptions of the TEACHH intervention. Caregivers in the TEACHH group were interviewed after the intervention was completed, ~1 month after enrollment. Caregivers in the SC group were interviewed after 6-month follow-up, at which time the toolkit was presented for review and feedback. An additional $20 was provided for caregivers who completed an interview.

Finally, we conducted in-depth interviews with pediatric primary care providers from the Rochester, NY metropolitan area. These interviews were similarly intended to gain PCP insights on the TEACHH intervention and component tools, explored their experiences with clinic-based asthma education, and identified perceived unmet home asthma management needs. PCPs did not need to have a patient enrolled in the TEACHH pilot to be interviewed. All PCPs received a single $30 gift card for completing a 30–45 minute interview over Zoom.

### Analysis

We originally planned to enroll a sample of 60 children (ages 5–11 years) and their caregivers over a 9-month period. Initial enrollment projections were informed by historic data on asthma-related admissions to GCH. However, we encountered less success with enrollment than anticipated, even after expanding the enrollment period to 12 months and increasing the upper age limit of eligibility to 13 years. It is now apparent that our difficulties with enrollment were heavily informed by a well-described reduction in asthma exacerbations and related hospitalizations seen across the US during the COVID-19 pandemic.^38,39^

The proposed sample was appropriate for the funding mechanism and anticipated resources required to conduct the study. Due to limitations in power resulting from the smaller-than anticipated sample size in this pilot study, however, we planned a descriptive-only approach to quantitative data without statistical comparisons. Transcriptions of recorded interviews with caregivers and pediatric PCPs were analyzed using an open coding approach. The primary analysis of transcripts and initial round of coding was completed by SF. Mind mapping software (Xmind version 24; Xmind LTD) was used for the development of themes and consolidation of codes with similar or overlapping meaning. A subsequent review and refinement of codes and themes was completed in partnership with JSH and other collaborators from the Catalyst Award.

### Limitations

The smaller sample size and altered trends in healthcare utilization described above may limit both the generalizability and reproducibility of findings. The preliminary feasibility assessment conducted was also narrow in scope; a future full-scale trial should include a comprehensive implementation assessment to better understand factors associated with successful intervention delivery and resource demands. Finally, although a prescription for preventive medication at the time of hospital discharge was required for enrollment, we did not make treatment recommendations or assess whether prescribed therapy was appropriate for a child’s level of severity. A future refinement of TEACHH might benefit from the addition of provider prompting, previously shown to improve the prescribing of guideline-based preventive therapy.^40^

## RESULTS

### Sample characteristics

We enrolled a total of 26 caregiver/child dyads between 11/8/2021–11/7/2022, with 13 randomized to each group. The mean age of enrolled children was 7.3 years, with an average recalled age at initial asthma diagnosis of 2.1 years (Table 1). A majority of enrolled children were female (58%), 35% identified as Black, and 12% identified as Hispanic. Two-thirds had public health insurance, and most (92%) had a family member with asthma. Most caregivers (85%) were female, nearly half were married or in a domestic partnership, 58% reported completing some education after high school, and 39% identified as a smoker. Nearly all of these children had a well child check in the previous 12 months (92%), and 58% of caregivers reported that their child had been prescribed a preventive medication.

### Feasibility of delivering TEACHH intervention

The main pilot study was found to be feasible, with 77% of all teaching visits completed as planned. This included the completion of all inpatient sessions, 85% of 1^st^ telehealth visits, and 69% of 2^nd^ telehealth visits. On average, first telehealth visits were completed 4 days after baseline (range: 2–8 days) and second telehealth visits were completed 25 days after baseline (range: 17–30 days).

### Key outcomes of interest

Final follow-up surveys were completed by 62% of caregivers. Both groups experienced improvements in child symptoms and caregiver quality of life over time (Table 2). Children in TEACHH experienced >2.5 additional SFDs compared with children in SC at both 2- and 4-month follow-up, with similar SFD reported at 6-months. Caregiver QOL was similar for both groups at 2- and 4-months, and slightly higher in the TEACHH group at 6-months reaching the MCID threshold. Ten children (38%) had an acute visit for asthma during the 12-months prior to baseline, while six children (23%) had an acute visit within 6-months of enrollment. More children in the TEACHH group required acute asthma visits at both baseline and 6-month follow-up.

### Results of Companion Qualitative Research

As part of the companion qualitative work funded by the ALA Catalyst Award, we interviewed 14 caregivers enrolled in the study (9 from TEACHH, 5 from SC). Five themes emerged from analyses of interview transcripts (approach to education, child-specific benefits, supporting home management after discharge, communication about asthma, and the use of TEACHH for other families). This Catalyst Award-funded work enabled verification that TEACHH was well-received by caregivers, who liked the approach to education and appreciated the active involvement of their children. Several caregivers expressed relief that they would not be solely responsible for teaching children about asthma, as might be the case without the intervention. We also gained important insight into lived experiences with learning about asthma and challenges with daily management. Caregivers described uncertainty around an asthma diagnosis when their children were young, and recalled drawing on personal or family experiences when figuring out how to manage their child’s asthma. Difficulty with identifying acute asthma symptoms and when to use rescue medication was reported by numerous caregivers, several of whom reporting relying on a store-bought home oximetry unit to help decide when to use albuterol. Caregivers shared that it can be difficult to ensure that recommended asthma care is delivered when children live in multiple homes and have multiple caregivers. The use of telehealth virtual visits for post-discharge education was viewed as a convenient way to minimize life disruptions and include multiple caregivers from different households.

We also interviewed 16 pediatric primary care providers (14 physicians, 2 nurse practitioners) with experience ranging from 2–34 years. 10 general pediatric practices were represented, including 4 urban practices (2 of which are pediatric residency training sites) and 6 suburban practices. Several perceptions of caregivers were shared by these providers. For example, providers expressed a similar uncertainty over initial asthma diagnosis, and how such uncertainty could be an impediment to teaching about asthma care. Previously described barriers to asthma education, including limited time and competing demands during visits, were observed to be ongoing concerns. Several providers indicated that supporting home management through teaching was less effective for children living in multiple residences, especially when only one caregiver is present for teaching in clinic. Opinions on when to involve children as participants were varied; some providers indicated that children should be involved at an early age, while others hesitated to directly engage early adolescents. TEACHH was viewed favorably across the pool of providers, with appreciation for the pictorial asthma action plans and perception that the TEACHH toolkit might be used piecemeal to provide flexible support as needed. A key barrier to implementing TEACHH at scale, or adapting the toolkit for clinic-based use, was the anticipated difficulty in completing pictorial action plans. This stemmed from the different appearances of generic medications, and a perceived lack of knowledge over which inhaled medication might be covered by insurance and/or dispensed.

### Discussion

Results from this pilot indicate that a novel program of patient-centered, health literacy-informed asthma education was feasible for delivering to children and caregivers in both hospital and virtual home settings. Although two participants were lost to follow-up after leaving the hospital, most participants in TEACHH successfully completed both telehealth visits within one month of discharge. The intervention was well-received by caregivers who liked the overall approach to teaching, appreciated the inclusion of children in learning activities, and used visual tools after discharge to build a routine of medication adherence. Several caregivers also felt that TEACHH would be appropriate for other families managing childhood asthma at home, and would be particularly helpful if delivered closer to the child’s initial diagnosis.

An initial review of data from follow-up surveys suggests that children in TEACHH may experience more SFD than children in SC within 4 months of enrollment. In contrast, more participants randomized to TEACHH required acute healthcare at both assessment points. Moreover, fewer TEACHH patients were on a preventive medication at baseline. The limited sample did not allow for robust statistical comparisons to provide further clarity about morbidity outcomes, and a larger study is needed to fully assess the influence of TEACHH on key asthma outcomes.

A key strength of TEACHH is the foundation of research that informed the intervention design. Caregivers of hospitalized children prefer to learn through hands-on demonstration coupled with teach-back, compared with only receiving written or video instructions.^41^ Inpatient teaching is most effective when bolstered by ongoing support,^14,42^ which should be initiated promptly after discharge and ideally feature continuity in relationship and messaging.^14,43^ A focus on home management skills and adherence strategies is particularly effective at decreasing hospital readmissions,^43^ as is the use of plain language and visual information.^8^

We know of no other study linking hospital-initiated education with virtual home visits to reinforce asthma teaching and improve management after discharge. Caregivers indicated broad acceptance of telehealth follow-up, endorsing the importance of convenience and flexibility of virtual visits after children had returned to their baselines of health. One respondent described how Zoom visits facilitated the participation of a second parent, while another appreciated not worrying about travel or sibling childcare. Most adults in the US report smartphone ownership,^44^ including families living in poverty. However, future studies should consider ways to ensure intervention access for patients who do not own or have access to a Zoom-compatible device.

We are also not aware of other studies using color/shape labels to help hospitalized patients differentiate between medications. Caregivers appreciated the use of visual and color-coded information for asthma medications, which is consistent with previous work indicating that some patients and caregivers rely on physical device characteristics (i.e., shape or color) to identify medications. A growing body of literature underscores the importance of medication identification in chronic disease management,^45–48^ yet families often confuse rescue and preventive inhalers.^49^ Caregiver difficulty with naming inhaled asthma medications is associated with lower adherence and more child symptoms.^33^ The use of visually coded stickers is a simple, low-cost strategy to facilitate accurate identification and promote adherence, particularly among children with developing literacy skills. Providers suggested that the pictorial action plans and stickers might be one of the more impactful components to the TEACHH intervention, though cited the lack of consistency in medication appearances as a potential barrier to implementing such a tool in their own clinics.

### Conclusion

TEACHH successfully addresses long-standing barriers to effective home management support by combining evidence-based approaches to asthma education with real-time virtual follow-up, visually coded medication labels, and active engagement of both child and caregiver. Data from the pilot study indicate that this novel approach to delivering patient-centered, technology-enhanced asthma education throughout the hospital-to-home transition is feasible to implement and well-received by learners.

### Significance and Implications

Asthma is a common childhood illness with significant disparities in care and high rates of preventable morbidity. Effective home management is essential to prevent exacerbations. Children hospitalized with asthma exacerbations are an important target for intervention, because they are at particularly elevated risk for future acute care use which can be costly. The transition from hospital-to-home is often a missed opportunity to provide home management support. Asthma education can promote effective home management by children and families, improve medication adherence, and decrease ACU. This pilot used a patient-centered, health literacy-based educational intervention, including virtual visits and color/shape medication labeling, to teach children and caregivers about home asthma management. A full-scale trial is now needed to determine the efficacy of TEACHH on patient-important asthma outcomes such as future acute healthcare use.

### Next Steps

While local patterns of asthma-related acute healthcare use have returned to pre-pandemic baselines, the University of Rochester is unlikely to provide care for enough hospitalized children with asthma to support a single site RCT. A multi-site trial of the TEACHH intervention may be needed to enroll a sample sufficient for appropriately powered hypothesis testing and will be considered in the future. It also bears consideration of whether the TEACHH intervention might be adapted to other clinical settings.

Uncontrolled asthma is a leading cause of pediatric ED visits in the US, with considerable disparities informing ED presentation and preventive asthma care alike. Similar to what is seen with hospitalizations, ED visits for asthma are an important risk factor for subsequent acute use. Dr. Halterman recently led the Telemedicine-Enhanced Asthma Management in the Emergency Department study (TEAM-ED; n=384), an RCT linking children (3–12 years) to primary care after discharge using school-based telemedicine.^50^ The program successfully increased PCP follow-up and prescriptions for preventive medications for subjects in the intervention group, but had a limited impact on adherence, symptoms or care utilization. Importantly, Dr. Halterman’s team demonstrated that a full-scale RCT could be conducted by enrolling patients from the two pediatric emergency departments in our region (GCH and Rochester General Hospital).

Dr. Halterman’s findings may indicate that patients and caregivers would benefit from additional education after an ED visit to support home management and increase medication adherence. In response, we proposed a new intervention for children presenting to the ED for asthma. The Telehealth-Enhanced Asthma Care for Home after the Emergency Room (TEACHER) intervention combines core elements of TEAM-ED (optimized PCP follow-up and preventive medication prescribing) and TEACHH (health literacy-informed education and self-management support).

We submitted an application to the NHLBI for R01 funding to conduct a full-scale RCT of TEACH-ER in October 2022. Several changes to the TEACHH intervention were indicated. Leaders of local pediatric ED sites were concerned about the duration of initial teaching and the potential to prolong length of stay. In response, we proposed that children randomized to TEACHER would be provided with brief (<5 minutes) ‘priming’ teaching focusing on essential asthma skills including how to use an MDI with spacer and indications for using rescue medications; the remaining teaching activities would be delivered during a pair of in-home telehealth visits. Like TEAM-ED, TEACH-ER would incorporate PCP follow-up, though encourage PCPs to use home-based telemedicine (rather than the school-based model or in-clinic care) when possible. Following data on the ages of patients most likely to seek ED asthma care, the age of eligibility was changed to 3–12 years. Unlike TEACHH, children at the lower end of this age range would not be expected to engage in teaching activities. We proposed that all teaching and skill building be directed primarily at caregivers, though with active inclusion of children ages 7–12 years when developmentally appropriate. Finally, we proposed an aim addressing dissemination and implementation considerations. The application was favorably reviewed in February 2023 and selected for funding, with initial notice of award in September 2023 (R01 HL169466). This exciting next step builds on the foundational work from the TEACHH pilot, and would not have been possible without financial support from the Agency for Healthcare Research and Quality.

## LIST OF PUBLICATIONS AND PRODUCTS

- [underlined: Peer-Reviewed Publications:]
  ○ Frey SM, Sanchez I, Fagnano M, Milne Wenderlich A, Mammen JR, Halterman JS. The Telehealth Education for Asthma Connecting Hospital and Home (TEACHH) Pilot Study. J Asthma. Published online ahead of print Oct 9, 2024.
- [underlined: Presentations:]
  ○ Frey SM, Sanchez I, Fagnano M, Milne Wenderlich A, Mammen JR, Halterman JS. Telehealth Education for Asthma Connecting Hospital and Home (TEACHH): A pilot randomized trial. Poster presentation, Pediatric Academic Societies. Toronto, ON, Canada. May 2024.
  ○ Frey SM, Fagnano M, Milne Wenderlich A, Mammen JR, Halterman JS. Caregiver experiences with asthma education and home management support. Poster presentation, Pediatric Academic Societies. Toronto, ON, Canada. May 2024.
  ○ Frey SM, Fagnano M, Milne Wenderlich A, Mammen JR, Halterman JS. Pediatric primary care provider experiences with delivering asthma education. Poster presentation, Pediatric Academic Societies. Toronto, ON, Canada. May 2024.
- [underlined: Manuscripts in Development:]
  ○ Frey SM, Fagnano M, Milne Wenderlich A, Mammen JR, Halterman JS. Caregiver experiences with asthma education and home management support.
    ▪ Anticipated submission: February 2025
  ○ Frey SM, Fagnano M, Milne Wenderlich A, Mammen JR, Halterman JS. Pediatric primary care provider experiences with delivering asthma education.
    ▪ Anticipated submission: March 2025

Table 1 Participant characteristics

| | Treatment Group
| Overall N=26 | TEACHH N=13 | SC N=13
Child characteristics
Age at the time of enrollment (yrs) | 7.3 (1.8) | 7.4 (1.8) | 7.2 (1.9)
Approximate age at the time of diagnosis (yrs) | 2.1 (1.7) | 2.3 (1.5) | 1.9 (2.0)
Gender (female) | 15 (58%) | 6 (46%) | 9 (69%)
Race (Black) | 9 (35%) | 6 (46%) | 3 (23%)
Race (White) | 11 (42%) | 6 (46%) | 5 (39%)
Race (Other) | 6 (23%) | 1 (8%) | 5 (38%)
Hispanic Ethnicity | 3 (12%) | 0 (0%) | 3 (23%)
Public health insurance | 17 (65%) | 9 (69%) | 8 (62%)
Another family member has asthma | 24 (92%) | 12 (92%) | 12 (92%)
Caregiver characteristics
Gender (female) | 22 (85%) | 11 (85%) | 11 (85%)
Martial status: married/domestic partnership | 12 (46%) | 6 (46%) | 6 (46%)
Highest level of education (>High School) | 15 (58%) | 7 (54%) | 8 (62%)
Identifies as a smoker | 10 (39%) | 6 (46%) | 4 (31%)
Access to preventive care
Well child check within past 12 months | 24 (92%) | 12 (92%) | 12 (92%)
Asthma action plan at home | 11 (42%) | 5 (39%) | 6 (46%)
Preventive medication reported | 15 (58%) | 5 (39%) | 10 (77%)

Data presented as either mean (SD) or N (%)

Table 2 Preliminary outcome data from follow-up caregiver surveys and chart review data

| Baseline | | | 2 Month Follow-up | | 4 Month Follow-up | | 6 Month Follow-up | | 6 Month Chart Review
| [underlined: Overall] N=26 | [underlined: TEACHH] N=13 | [underlined: SC] N=13 | [underlined: TEACHH] N=8 | [underlined: SC] N=10 | [underlined: TEACHH] N=7 | [underlined: SC] N=10 | [underlined: TEACHH] N=7 | [underlined: SC] N=9 | [underlined: TEACHH] N=13 | [underlined: SC] N=13
Asthma-related ED and hospital visits (any)^*^ | 10 (39%) | 6 (46%) | 4 (31%) | | | | | | | 4 (31%) | 2 (15%)
Caregiver Quality of Life (past wk) ** | 4.4 (1.2) | 4.5 (1.2) | 4.3 (1.2) | 6.4 (0.6) | 6.0 (1.1) | 6.6 (0.3) | 6.2 (0.9) | 6.8 (0.3) | 6.3 (1.1)
Symptom-Free Days (past 14d) | 7.5 (4.7) | 7.6 (4.2) | 7.3 (5.3) | 11.9 (1.6) | 9.1 (5.9) | 13.0 (0.8) | 10.2 (4.0) | 10.1 (4.8) | 10.4 (3.7)

Data presented as either mean (SD) or N (%)

* Per review of local medical records; baseline value reflects healthcare use during the 12 months prior to baseline

** Pediatric Asthma Caregiver Quality of Life Questionnaire; scale 1–7 points, with higher scores indicating better quality of life.

## REFERENCES

1 Akinbami LJ, Moorman JE, Bailey C, Zahran HS, King M, Johnson CA, Liu X. Trends in asthma prevalence, health care use, and mortality in the United States, 2001–2010. NCHS Data Brief. 2012(94):1–8.
2 Most Recent Asthma Data. [Internet]. Atlanta: Centers for Disease Control and Prevention (US), 2019. (Accessed October 10, 2024). Available from: https://www.cdc.gov/asthma/archivedata/2019/2019_archived_national_data.html
3 Rui P, Kang K. National Hospital Ambulatory Medical Care Survey: 2015 Emergency Department Summary Tables. 2016. (Accessed October 24, 2019). Available from: https://www.cdc.gov/nchs/data/nhamcs/web_tables/2015_ed_web_tables.pdf
4 Akinbami LJ, Moorman JE, Simon AE, Schoendorf KC. Trends in racial disparities for asthma outcomes among children 0 to 17 years, 2001–2010. J All Clin Immunol. 2014;134(3):547–53.
5 Crocker D, Brown C, Moolenaar R, Moorman J, Bailey C, Mannino D, Holguin F. Racial and ethnic disparities in asthma medication usage and health-care u tilization: data from the National Asthma Survey. Chest. 2009;136(4):1063–71.19567492
6 Beck AF, Moncrief T, Huang B, Simmons JM, Sauers H, Chen C, Kahn RS. Inequalities in neighborhood child asthma admission rates and underlying community characteristics in one US county. J Pediatr. 2013;163(2):574–80.23522864
7 Mitchell SJ, Bilderback AL, Okelo SO. Racial Disparities in Asthma Morbidity Among Pediatric Patients Seeking Asthma Specialist Care. Acad Pediatr. 2016;16(1):64–7.26329015
8 Krupp NL, Fiscus C, Webb R, Webber EC, Stanley T, Pettit R, Multifaceted quality improvement initiative to decrease pediatric asthma readmissions. J Asthma. 2017;54(9):911–8.28118056
9 Zipkin R, Schrager SM, Nguyen E, Mamey MR, Banuelos I, Wu SS. Association between pediatric home management plan of care compliance and asthma readmission. J Asthma. 2017;54(7):761–7.27929691
10 Gay JC, Agrawal R, Auger KA, Del Beccaro MA, Eghtesady P, Fieldston ES, Rates and Impact of Potentially Preventable Readmissions at Children's Hospitals. J Pediatr. 2015;166(3):613–U909.25477164
11 Expert panel report III: guidelines for the diagnosis and management of asthma. NIH publication No. 07–4051. Bethesda, MD: U.S. Department of Health and Human Services; National Institute of Health; National Heart, Lung, and Blood Institute; National Asthma Education and Prevention Program, 2007.
12 Kirk S, Beatty S, Callery P, Gellatly J, Milnes L, Pryjmachuk S. The effectiveness of self-care support interventions for children and young people with long-term conditions: a systematic review. Child Care Hlth Dev. 2013;39(3):305–24.
13 Liu WY, Jiesisibieke ZL, Tung TH. Effect of asthma education on health outcomes in children: a systematic review. Arch Dis Child. 2022;107(12):1100–5.35197244
14 Auger KA, Kenyon CC, Feudtner C, Davis MM. Pediatric hospital discharge interventions to reduce subsequent utilization: a systematic review. J Hosp Med. 2014;9(4):251–60.24357528
15 Solan LG, Beck AF, Brunswick SA, Sauers HS, Wade-Murphy S, Simmons JM, The Family Perspective on Hospital to Home Transitions: A Qualitative Study. Pediatrics. 2015;136(6):E1539–E49.26620060
16 Kessels RP. Patients' memory for medical information. J R Soc Med. 2003;96(5):219–22.12724430
17 Glick AF, Farkas JS, Nicholson J, Dreyer BP, Fears M, Bandera C, Parental Management of Discharge Instructions: A Systematic Review. Pediatrics. 2017;140(2).
18 Paasche-Orlow MK, Parker RM, Gazmararian JA, Nielsen-Bohlman LT, Rudd RR. The prevalence of limited health literacy. J Gen Intern Med. 2005;20(2):175–84.15836552
19 Lintzenich A, Teufel RJ, 2nd, Basco WT, Jr. Under-utilization of controller medications and poor follow-up rates among hospitalized asthma patients. Hosp Pediatr. 2011;1(1):8–14.24510924
20 Andrews AL, Bundy DG, Simpson KN, Teufel RJ, Harvey J, Simpson AN. Inhaled Corticosteroid Claims and Outpatient Visits After Hospitalization for Asthma Among Commercially Insured Children. Acad Pediatr. 2017;17(2):212–7.28259341
21 Frey SM, Fagnano M, Halterman JS. Caregiver education to promote appropriate use of preventive asthma medications: what is happening in primary care? J Asthma. 2016;53(2):213–9.26288255
22 Orrell-Valente JK, Jarlsberg LG, Hill LG, Cabana MD. At what age do children start taking daily asthma medicines on their own? Pediatrics. 2008;122(6):e1186–92.19047221
23 Carpenter DM, Ayala GX, Williams DM, Yeatts KB, Davis S, Sleath B. The relationship between patient-provider communication and quality of life for children with asthma and their caregivers. J Asthma. 2013;50(7):791–8.23730868
24 Monaghan M, Hilliard M, Sweenie R, Riekert K. Transition readiness in adolescents and emerging adults with diabetes: the role of patient-provider communication. Curr Diab Rep. 2013;13(6):900–8.24014075
25 Beresford BA, Sloper P. Chronically ill adolescents' experiences of communicating with doctors: A qualitative study. J Adol Health. 2003;33(3):172–9.
26 Cahill P, Papageorgiou A. Triadic communication in the primary care paediatric consultation: a review of the literature. Br J Gen Pract. 2007;57(544):904–11.17976292
27 Sleath BL, Carpenter DM, Sayner R, Ayala GX, Williams D, Davis S, Child and caregiver involvement and shared decision-making during asthma pediatric visits. J Asthma. 2011;48(10):1022–31.22022958
28 Yin HS, Gupta RS, Tomopoulos S, Wolf MS, Mendelsohn AL, Antler L, Readability, suitability, and characteristics of asthma action plans: examination of factors that may impair understanding. Pediatrics. 2013;131(1):e116–26.23209106
29 Frey SM, Jones MR, Goldstein N, Riekert K, Fagnano M, Halterman JS. Knowledge of Inhaled Therapy and Responsibility for Asthma Management Among Young Teens With Uncontrolled Persistent Asthma. Acad Pediatr. 2018;18(3):317–23.29369804
30 McQuaid EL, Kopel SJ, Klein RB, Fritz GK. Medication adherence in pediatric asthma: reasoning, responsibility, and behavior. J Pediatr Psychol. 2003;28(5):323–33.12808009
31 Kaplan A, Price D. Treatment Adherence in Adolescents with Asthma. J Asthma Allergy. 2020;13:39–49.32021311
32 Gray WN, Netz M, McConville A, Fedele D, Wagoner ST, Schaefer MR. Medication adherence in pediatric asthma: A systematic review of the literature. Pediatr Pulmonol. 2018;53(5):668–84.29461017
33 Frey SM, Fagnano M, Halterman J. Medication Identification Among Caregivers of Urban Children With Asthma. Acad Pediatr. 2016;16(8):799–805.27130812
34 Pradel FG, Hartzema AG, Bush PJ. Asthma self-management: the perspective of children. Patient Educ Couns. 2001;45(3):199–209.11722856
35 Halterman JS, Fagnano M, Tajon RS, Tremblay P, Wang H, Butz A, Effect of the School-Based Telemedicine Enhanced Asthma Management (SB-TEAM) Program on Asthma Morbidity: A Randomized Clinical Trial. JAMA Pediatr. 2018;172(3):e174938.29309483
36 Halterman J, Szilagyi P, Fisher S, Fagnano M, Tremblay P, Conn K, A randomized controlled trial to improve care for urban children with asthma: results of the School-Based Asthma Therapy trial. Arch Pediatr Adolesc Med. 2011;165:262–8.21383275
37 Juniper EF, Guyatt GH, Feeny DH, Ferrie PJ, Griffith LE, Townsend M. Measuring quality of life in the parents of children with asthma. Qual Life Res. 1996;5(1):27–34.8901364
38 Hurst JH, Zhao C, Fitzpatrick NS, Goldstein BA, Lang JE. Reduced pediatric urgent asthma utilization and exacerbations during the COVID-19 pandemic. Pediatr Pulmonol. 2021;56(10):3166–73.34289526
39 Sheehan WJ, Patel SJ, Margolis RHF, Fox ER, Shelef DQ, Kachroo N, Pediatric asthma exacerbations during the COVID-19 pandemic: Absence of the typical fall seasonal spike in Washingon, DC. J All Clin Immunol Pract. 2021;9(5):2073–6.
40 Halterman JS, Fagnano M, Tremblay PJ, Fisher SG, Wang H, Rand C, Prompting Asthma Intervention in Rochester-Uniting Parents and Providers (PAIR-UP): A Randomized Trial. JAMA Pediatr. 2014;168(10):e141983.25288141
41 Vepraskas SH, O'Day P, Zhang L, Simpson P, Gage S. Parents Support Teach-back, Demonstration, and a Postdischarge Phone Call to Augment Discharge Education. Hosp Pediatr. 2018;8(12):778–84.30464003
42 Hansen LO, Young RS, Hinami K, Leung A, Williams MV. Interventions to reduce 30-day rehospitalization: a systematic review. Ann Intern Med. 2011;155(8):520–8.22007045
43 Feltner C, Jones CD, Cene CW, Zheng ZJ, Sueta CA, Coker-Schwimmer EJ, Transitional care interventions to prevent readmissions for persons with heart failure: a systematic review and meta-analysis. Ann Intern Med. 2014;160(11):774–84.24862840
44 Mobile Fact Sheet Washington [Internet]. Washington, D.C.: PEW Research Center; 2018 (Accessed October 3, 2022). Available from: http://pewinternet.org/fact-sheet/mobile
45 Kesselheim AS, Misono AS, Shrank WH, Greene JA, Doherty M, Avorn J, Choudhry NK. Variations in pill appearance of antiepileptic drugs and the risk of nonadherence. JAMA Intern Med. 2013;173(3):202–8.23277164
46 Lenahan JL, McCarthy DM, Davis TC, Curtis LM, Serper M, Wolf MS. A Drug by Any Other Name: Patients' Ability to Identify Medication Regimens and Its Association With Adherence and Health Outcomes. J Health Comm. 2013;18:31–9.
47 Kesselheim AS, Bykov K, Avorn J, Tong A, Doherty M, Choudhry NK. Burden of changes in pill appearance for patients receiving generic cardiovascular medications after myocardial infarction: cohort and nested case-control studies. Ann Intern Med. 2014;161(2):96–103.25023248
48 Persell SD, Bailey SC, Tang J, Davis TC, Wolf MS. Medication reconciliation and hypertension control. Am J Med. 2010;123(2):182 e9- e15.
49 Akinbami LJ, Salo PM, Cloutier MM, Wilkerson JC, Elward KS, Mazurek JM, Primary care clinician adherence with asthma guidelines: the National Asthma Survey of Physicians. J Asthma. 2019:1–13.
50 Halterman JS, Fagnano M, Tremblay P, Butz A, Perry TT, Wang HY. Effect of the Telemedicine Enhanced Asthma Management Through the Emergency Department (TEAM-ED) Program on Asthma Morbidity: A Randomized Controlled Trial. J Pediatr. 2024;266.

## Core Team Members for R03 Pilot

- Co-Investigators:
  ○ Jill Halterman, MD, MPH; Professor and Chair, Department of Pediatrics; University of Rochester School of Medicine and Dentistry
  ○ Hongyue Wang, PhD; Research Associate Professor of Biostatistics; University of Rochester School of Medicine and Dentistry
- Asthma Educator:
  ○ Ignacio Sanchez, MPH; University of Rochester School of Medicine and Dentistry

Organization
- University of Rochester

## Acknowledgement of Agency support

• This work supported by grant R03HS028033 from the Agency for Healthcare Research and Quality (AHRQ). The contents of this project are solely the responsibility of the authors, and do not necessarily represent the official views of the Agency for Healthcare Research and Quality.