# School-Based Tele-Physiatry Assistance for Rehabilitative and Therapeutic Services (STARS) for Children with Special Health Care Needs Living in Rural and Underserved Communities

AHRQ FINAL PROGRESS REPORT

## PURPOSE (Objectives of study)

### Objectives of study

In California, the California Children’s Services (CCS) Medical Therapy Program (MTP) is a network of multidisciplinary school-based clinics called Medical Therapy Units (MTUs). MTUs provide comprehensive medical care to children with special health care needs, providing durable medical equipment, orthotics, and therapy services. Unfortunately, many children living in rural and underserved communities are unable to receive appropriate services due to the regionalization of qualified specialist physicians known as pediatric physiatrists. To increase access of healthcare for these children, we implemented a hybrid model of care using telehealth to deliver pediatric physiatrist medical direction to MTUs located in underserved communities. This “hybrid” model of care involved the pediatric physiatrist using telehealth to join the patient and therapists in the designated MTU. In 2020, because of the COVID-19 pandemic, we included an additional cohort to compare a third model of care (all-virtual) where the physiatrist and therapists used telehealth to join the patient/parent in their home. This was added in response to shelter-in-place orders that temporarily closed all schools and school-based MTUs.

Our objectives were to compare outcomes from these three models of care: 1) in-person care with the physiatrist, therapists, and patient in the MTU (in-person model of care); 2) therapists and patient in the MTU with the pediatric physiatrist present over telehealth (hybrid model of care); and 3) physiatrist, therapists, and patient/parent all joining the encounter through telehealth (all-virtual model of care). Outcomes included: 1) parent experience of care; 2) parent and provider perception of quality of care; and 3) costs of care from the perspective of the payer. For the cost analysis, we compared the in-person model of care to the hybrid model of care.

## SCOPE (Background, Context, Settings, Participants, Incidence, Prevalence)

### Background

The MTP is established in each of California’s 58 counties, however, many counties do not have a MTU because of the lack of available pediatric specialists in their communities. As a result, children from many counties must travel long distances to counties where MTUs are present.

According to MTP guidelines, a physician director is to treat all eligible children at a minimum of either 6- or 12-month intervals. In the standard of care (in-person model of care), the specialist physicians (pediatric physiatrist) traveled to the MTUs in their county and/or adjacent counties to provide this care. The travel demanded physiatrists to travel to the MTUs, which required many hours of travel and overnight stays. It has been increasingly difficult for MTPs to sustain consistent physician medical directorship onsite because of these long travel distances. In counties where pediatric physiatrists couldn’t travel, rural MTUs were forced to contract with non-specialist physicians or close their MTU and have the children/families travel to far-away counties to receive care at MTUs that had physician oversight.

Due to unforeseen challenges we encountered at the start of our study, we made modifications to several elements of our study. First, we originally proposed sites with a control group that received care from non-pediatric specialists or community providers. Sites included in the original proposal were MTUs led by non-pediatric physicians. However, following receipt of the funding, these sites successfully recruited pediatric physicians and we were unable to include them as our original control group. Second, COVID-19 also significantly impacted data collection of hip surveillance adherence. Following the pandemic shutdown, hip surveillance surveys could not be administered or collected due to all sites temporarily switching to all virtual visits. The pandemic forced MTUs to close and prevented providers from conducting in-person examinations required for appropriate, evidence based hip surveillance. As a result, we pivoted our study comparison groups and hypothesized that pediatric physiatrist care provided via telehealth (hybrid model of care) would result in equal patient experience and equal perceived quality of care for parents and therapists when compared to in-person care (in-person model of care). Because of the COVID-19 pandemic, we were able to evaluate a third model of care where all participants, including the pediatric physiatrist, the therapists, and the patient/family, all participated in their encounter over telehealth (all-virtual model of care). As a result, we were able to effectively pivot our study and include all three models of care.

### Context

Pediatric physiatry services are regionalized. As a result, patients and families living in rural communities face many barriers to access including parents and other caregivers missing work, children missing school, and costs and risks associated with travel.^1–3^ We hypothesized that telehealth might improve access and allow physicians the ability to provide care in these rural communities where they might not be able to travel. Prior to this study, there had been no research evaluating parent experience and perception of quality of care using telehealth for MTU encounters in rural communities.

### Settings

This study originally proposed to study the care at 8 MTU sites. Five of the 8 sites we approached agreed to participate. After the study was initiated, and partly due to the expansion of telehealth following the COVID-19 pandemic, 12 additional MTU sites agreed to participate. In total, this study involved 17 MTUs in 11 counties throughout California. For the analyses, we excluded data from 4 sites who contributed data only from the all-virtual model of care.

### Participants

Regardless of which model of care was being used, all parents of patients receiving care in the MTUs were eligible for participation in the study. Clinic days at each MTU were randomly assigned to receive in-person or hybrid care on an alternating schedule. Parents were approached to potentially enroll in the study at the beginning of their MTU encounter. If parents agreed to participate in the study, they were asked to complete a “parent survey” on paper or an iPad after the visit (for in-person model of care and the hybrid model of care) or via e-mail following the visit (for the hybrid model of care and the all-virtual model of care). Therapists and physicians also completed therapist and physician surveys, respectively, after each encounter for those parents that were enrolled in the study.

### Incidence

The MTP program guides the therapy and comprehensive medical management of children with special health care needs and serves nearly 23,000 children across California.^4^ Care is provided in a school based MTU. As shown in the California map (Appendix A), counties have varying types and numbers of physicians, making MTU availability differing among counties. MTUs in 26 counties (44.8%) have at least one specialized pediatric physiatrist providing in-person care for the MTUs. MTUs in 13 counties (22.4%) have two or more types of providers serving their MTUs, including pediatric physiatrists, general pediatricians, and orthopedic surgeons. MTUs in 10 counties (17.2%) have a general pediatrician as the only provider providing care. MTUs in 6 counties (10.3%) do not have any type of physician providing care to affected children in their county. Lastly, 3 counties (5.2%) do not have any MTUs within their county.

## METHODS (Study Design, Data Sources/Collection, Interventions, Measures, Limitations)

### Setting and system description

At the onset of the study, there were 8 rural MTUs served by an in-person pediatric physiatrist from our regional children’s hospital. We approached all 8 for their willingness to participate in this study and adopt the hybrid model of care and 5 agreed to participate. The 5 participating MTUs were in rural areas, with distances ranging from 48 – 107 miles from our children’s hospital. Following the start of the study, 12 additional MTUs joined the study, in part because of the COVID-19 pandemic and the adoption of the “all-virtual model” in which physiatrists, therapists, and families joined encounters virtually. As a result, there were 17 MTU sites included in the study.

### Study Design

We originally designed a noninferiority, cluster-randomized crossover study where MTUs were randomized to clinic days assigned to either the in-person model of care or the hybrid model of care. Clinic days subsequently alternated between the in-person model of care and the hybrid model of care. All patients that attended clinic at the MTU on a particular day would have randomly received either type of care model. Both the in-person model of care and the hybrid model of care required the patient and parent to travel to the local MTU and were scheduled between 1 and 4 times per year, as determined by their medical needs. Following the onset of the COVID-19 pandemic, clinics were all forced to adopt the all-virtual model of care. Following this change, a convergent, parallel, mixed methods design was used to analyze all 3 forms of care from all MTU sites recruited from January 2019 – January 2022. Ultimately, four sites were excluded from the data analysis because they only contributed data for the all-virtual model of care. Lastly, for the cost analyses, we compared the hybrid model of care to the in-person model of care from the perspective of CCS (the payor).

### Data Sources/Collection

All study surveys were made available in paper form, electronic form with iPad, or e-mail, and were administered to the parent just after the completion of the encounter. Staff members at each participating MTU assisted in survey distribution. Surveys were also administered to providers following the encounter, including the MTU therapists and UC Davis pediatric physiatrists.

We also collected qualitative data through 6 focus groups that consisted of 18 parents of patients, 3 pediatric physiatrists, and 8 physical and occupational therapists.

For our cost analysis, we calculated a “counter-factual” cost by assuming the hybrid model of care encounters receiving in-person care and in-person encounters receiving the hybrid model of care.

### Interventions

The MTUs began participation in the study at different times throughout the study period, and as a result, enrollment start dates were staggered. Therefore, some MTUs conducted more clinics than others. The hybrid model of care used a video software solution to connect from the physiatrist side to a pole-mounted monitor-computer equipped with a USB, high-definition video camera with remote pan-tilt-zoom capabilities. A standardized musculoskeletal clinical exam was established and reviewed with therapists prior to the initiation of hybrid model of care encounters. For the in-person model of care, the physiatrist would perform this exam in person at the MTU.

From January 2019 to February 2020, this clinic randomization scheme was conducted between the in-person model of care and the hybrid model of care. After the shelter-in-place orders were placed in March 2020, both the in-person and hybrid models of care were temporarily suspended, and data was collected on the all virtual model of care. At the onset of COVID-19, all clinics used the all-virtual model from April 2020 through March 2021. From April 2021 through November 2021, 13 of the 17 sites reverted back to using both in-person and hybrid models. The 4 remaining sites continued to use the all-virtual model of care.

### Measures

To measure patient experience of care, we included and adapted 6 questions from surveys developed by the Consumer Assessment of Healthcare Providers and Systems (CAHPS).^5^ The CAHPS surveys are used nationally to assess quality of care from the patient point of view. The questions used helped determine perceptions of quality of care using telehealth (Appendix B).

Physiatrists and therapists were requested to complete an electronic survey within 48 hours of a patient encounter. The survey asked providers to rate their experience and quality of care provided on a scale of 1 – 7 (Appendix C). Following visits using the hybrid and all-virtual models of care, provider surveys also included questions on the quality of the video, audio, and overall telehealth experience on a five-point scale.

We also used mixed effects regression to determine differences in mean parent experience score among the three models of care. A summary score was created for patient experience by normalizing each CAHPS survey question to a 0 – 1 scale and averaged the five normalized scores. We adjusted for patient age, sex, site, and visit year as fixed effects and the patient’s unique identifier as a random effect, to account for within-patient residual correlation across multiple visits. We repeated this approach for each of the other two parent experience questions. For therapist surveys, we used mixed effects regression models and analyzed each survey question separately, specifying random effects at the site level. The three physician survey measures were analyzed using ordinary least squares regression. All analyses were completed using Stata version 17.0.^6^

We also conducted 6 focus groups to gather qualitative insights on the different models of care. Four focus groups included a total of 18 parents, 1 focus group included 3 pediatric physiatrists who serve the MTUs, and 1 focus group included 8 physical and occupational therapists at the MTUs. Parents were recruited by phone and providers via email. Focus group interviews were approximately one hour and were conducted through Zoom. These interviews were conducted as discussions on the three models of care guided by the research team. Participants were encouraged to interact with one another to create a less structured discussion environment. The research team then coded interview transcripts using a constant comparative method to generate a set of themes and categories.^7^

From the payer’s perspective, the daily cost for physician compensation was high for the in-person model of care compared to the hybrid model of care. This included travel time and clinical care time. We calculated a “counter-factual” cost by assuming the hybrid model of care encounters receiving in-person care and in-person encounters receiving the hybrid model of care. Our analysis estimated the change in cost from a change in encounter type for each situation. For the first cost comparison, we tested the difference of the means of the 2 groups (in-person vs hybrid) using t-tests. For the second cost comparison, we tested the means of the two groups (in-person vs hybrid) separately by computing a difference between the cost of the actual visit and the cost of the visit had it been conducted using the hybrid model of care or vice versa. These statistical tests were conducted as t-tests.

## RESULTS (Principal Findings, Outcomes, Discussion, Conclusions, Significance, Implications)

### Principal Findings

We found no differences between the parent experience scores for the three models of care: the in-person model, the hybrid model, and the all-virtual model. Physicians and therapists rated quality of care, provision of parent education, and physical exam all lower when care was provided using the all-virtual model of care, compared to the other two models of care. However, providers (physicians and therapists) were equally satisfied with the quality of care measures for the in-person and hybrid models of care. Our cost analysis from the payer’s perspective showed that costs were $100 higher in the in-person model of care. Cost savings were primarily a result of lower mileage reimbursement costs in the hybrid model of care, more than offsetting the equipment costs, maintenance, and technical support.

### Outcomes

A total of 2,455 visits were completed for 1,281 unique patients: 507 in-person visits, 246 hybrid visits, and 1,702 all-virtual visits. Parents of 253 unique patients (19.8%) completed 312 surveys, or 12.7% of eligible encounters. Table 1 shows demographic characteristics of all eligible patients and of the subset of patients whose parents completed at least one survey. Among children of respondents, 25 (9.8%%) had at least one in-person visit, 9 (3.5%) had at least one hybrid visit, and 40 (15.8%) had at least one all-virtual visit. 179 children of respondents (70.7%) experienced more than one type of visit.

Parent Experience Scores: Normalized mean parent experience scores were 0.97 for in-person visits, 0.98 for hybrid visits, and 0.96 for all-virtual visits. These mean scores were not significantly different. Table 2 shows results from the mixed effects regression for parent experience score and parent satisfaction with the visit. There were no significant differences in parent experience for the hybrid model compared to the in-person model (AMD:-0.005, 95% CI: -0.02 to 0.01, p=0.35) or for the all-virtual model compared to the in-person model (AMD: -0.11, 95% CI: -0.03 to 0.01, p=0.34). There was also no difference in scores between the virtual model compared with the hybrid model of care (adjusted mean difference: 0.006, 95% CI: -0.02 to 0.03, p=-0.64).

Therapist Quality of Care Scores: Thirty-five therapists at participating MTUs completed 603 surveys during the study period. Normalized mean therapist-reported quality scores were 0.92 for in-person visits, 0.91 for hybrid visits, and 0.76 for all-virtual visits. Normalized mean scores for therapist confidence that the family was educated about the care plan were 0.93 for in-person visits, 0.93 for hybrid visits, and 0.84 for all-virtual visits. Therapists reported significantly lower quality of care and confidence in family education for the all-virtual visits compared to the in-person and hybrid models (AMD for quality: -0.18, 95% CI: -0.29 to -0.07, p<0.001; AMD for education: -0.10, 95% CI: -0.14 to -0.06, p<0.001). No difference was found between the hybrid and in-person models.

Physiatrist Quality of Care Scores: The 3 pediatric physiatrists that participated in the MTU program completed 343 surveys during the study period: 130 for in-person visits, 109 for hybrid visits, and 104 for all-virtual visits. Physicians reported significantly lower average mean differences in quality of care, quality of physical exam, and confidence that the family was educated about the care plan for all-virtual visits compared to the in-person model (AMD for quality: -0.19, 95% CI: -0.21 to -0.17, p<0.001; AMD for physical exam: -0.41, 95% CI: -0.46 to -0.37, p<0.001; AMD for education: -0.10, 95% CI: -0.12 to -0.08, p<0.001) and similarly lower differences for the all-virtual model compared to the hybrid model. We found no differences between the in-person and hybrid models.

Qualitative results were drawn from 18 parents that participated in the focus groups. Most (N=16) had experienced both in-person care and all-virtual care and 8 had experiences with all three models of care. Eight therapists participated in the therapist focus group, and all 3 pediatric physiatrists participated in the physician focus group.

Table 3 shows the results matrix with quotes for each qualitative theme. Parent, therapist, and physician participants overwhelmingly found the all-virtual visits to be of lower quality than the other two models of care. Lack of physical touch was mentioned in all groups as a barrier to quality care. Engaging pediatric patients over the all-virtual model of care was also another challenge. Parents found it difficult to engage their children during the all-virtual visits. Physicians and therapists also mentioned low quality of visits when families were in the car or had difficulty positioning the video correctly.

Finally, from the payer’s perspective, the daily cost for physician travel time and clinical care time was found to be higher for in-person visits compared to the hybrid visits. The analysis considered the cost implications of switching the in-person model of care to the hybrid model of care and vice versa. For in-person visits, the daily cost savings of changing these to hybrid visits is nearly $100 per day on average (P=.001). For hybrid visits, the daily cost savings is negative, meaning changing hybrid visits compared to in-person would cost CCS nearly $105 more per day on average (P<.05). All cost differences between in-person and hybrid models of care were statistically significant (P=.001).

### Discussion

Our study demonstrated that the hybrid model of pediatric physiatry care is an acceptable, high-quality, and lower cost alternative compared to in-person visits. Quantitative results of survey data found no differences in the ratings of parent experience or physician- and therapist-reported confidence in quality of care provided, provision of education to the parent, and the ability to conduct a sufficient physical exam. Qualitative results demonstrated that the hybrid model of care also provided an excellent alternative that results in equal quality of care for children receiving physiatry services. This is important because our study suggests that the use of telehealth to deliver a hybrid model of care is likely an effective and patient-centered model of care alternative to in-person care. The implications being that children living in rural and underserved communities that need pediatric physiatry services can and should consider this convenient model of care using telehealth.

In contrast, our study found that all-virtual visits were rated significantly lower by physicians and therapists. Focus group feedback mentioned that visits were often unsuccessful due to environmental distractions at home, issues with technology, poor internet, challenges positioning the camera, and other difficulties related to conducting a physical exam. However, parent experience survey scores were not significantly lower for all-virtual visits. Qualitative data showed that although parents perceived all-virtual visits to be lower in quality, they often remained deeply attached to their pediatric physiatrists and therapists, who they saw as working hard to provide continuity of care through a difficult time. Because parent experience survey questions focused on the interaction with the provider, it is not surprising that these scores remained high even when parents in focus groups overwhelmingly expressed that they did not prefer the all-virtual visits. This is also important because our study suggests that in-person and/or hybrid models of care should likely not be replaced by the all-virtual model of care for this patient population.

### Limitations

Our study had several limitations. Our initial proposal to have non-pediatric providers at sites as a control group were not included due to sites having recruited pediatric providers shortly after receiving funding. Additionally, the original trial design was disrupted by the COVID-19 pandemic, which did not allow for a controlled allocation of models of care throughout the study. We were also unable to collect data on hip surveillance adherence due to MTUs shutting down. However, we anticipated that the pandemic would have a similar effect on the MTUs and patients because all sites were forced to adopt the all-virtual model at the same time and parents did not select the visit type. Second, survey data was anonymized throughout collection and could not be traced back to individual patients or physiatrists. Third, focus group data was collected only from a relatively small number of parents, physicians, and therapists. In addition, we did not conduct qualitative data collection in other languages, and therefore did not capture the experience of families who do not speak English. Nevertheless, qualitative findings still provided insights into the potential explanations behind quantitative results.

In our cost analysis of the hybrid model of care, we focused on physician payment cost savings at the payer level and did not explore the potential effects on families traveling to a specialist physician appointment. These potential effects may have included lost wages, childcare for other children, travel costs, and intolerance of long car rides by children with special health care needs.^8^ In addition, we didn’t consider the upfront costs of the telehealth equipment, nor did we determine the number of telehealth visits that would be required to recover the startup costs.

### Conclusions

Our findings suggest that parents, therapists, and physicians find a hybrid model of care as an acceptable alternative to an in-person model of care and maintains the quality of care and facilitates parent education. Our findings also found that this hybrid model of care is associated with an average cost savings of $100 per clinic to the payer. All-virtual models may be appropriate for specific circumstances but are perceived as lower quality for routine visits. Future research exploring implementation of these models and the appropriate uses of each would be valuable for providing practical guidance.

### Implications

Our study demonstrated that a hybrid model of care could be used to expand access to pediatric physiatry care in California and potentially, around the nation. These findings are important and relevant for regions where few pediatric physiatrists serve geographically large areas and access to specialty care may be limited, as demonstrated in Appendix A. The in-person care model used as a comparison in our study involved the pediatric physiatrist driving to the MTUs, sometimes located more than 100 miles from the physiatrist’s original location. Because the hybrid model of care removes travel reimbursement, the payer has reported that the program is a cost-saving program and would be beneficial to invest in.

In some parts of California, the hybrid model of healthcare could be very helpful for certain families. These families often receive care at schools where the physicians must travel long distances to the school-based clinics. Having physicians limit travel to distant clinics would disproportionally affect those who live in rural areas, those with other children at home, and families that are socioeconomically disadvantaged. The hybrid model we present results in improved access to pediatric physiatrists and receive higher quality of care.

Table 1 Sample Characteristics

| All patients (N=1,281) | Patients represented in parent experience survey (N=253)
Models of care experienced, N (%)
In-person only | 109 (8.5) | 25 (9.8)
Hybrid only | 44 (3.4) | 9 (3.5)
All-virtual only | 700 (54.6) | 40 (15.8)
More than one visit type | 428 (33.4) | 179 (70.7)
Sex, N (%)
Female | 572 (44.7) | 120 (47.4)
Male | 709 (55.4) | 133 (52.6)
Race/Ethnicity, N (%)
Hispanic | 364 (28.4) | 62 (24.5)
White | 380 (29.7) | 66 (26.1)
Black | 108 (8.4) | 25 (9.9)
Asian | 93 (7.3) | 23 (9.1)
Unknown | 336 (26.2) | 77 (30.4)
Age at first visit in years, mean (SD) | 10.7 (5.3) | 10.9 (5.5)
Distance from site to UCDCH in miles, mean (SD) | 65.8 (76.7) | 47.1 (28.9)

Table 2 Pairwise contrasts from mixed effects multiple regression for normalized mean parent experience score, parent satisfaction with quality of care, therapist confidence in quality of care, therapist confidence in parent education, physician confidence in quality of care, physician confidence in parent education, and physician confidence in physical exam

| Coefficient | 95% CI | p-value
Parent experience score
Hybrid compared with in-person | −0.005 | −0.002, 0.01 | 0.35
All-virtual compared with in-person | −0.11 | −0.03, 0.01 | 0.34
All-virtual compared with hybrid | −0.006 | −0.03, 0.02 | 0.64
Parents: felt satisfied with quality of care received
Hybrid compared with in-person | −0.03 | −0.06, 0.004 | 0.09
All-virtual compared with in-person | −0.002 | −0.06, 0.06 | 0.94
All-virtual compared with hybrid | 0.02 | −0.05, 0.10 | 0.53
Therapists: felt confident in quality of care
Hybrid compared with in-person | −0.01 | −0.10, 0.08 | 0.84
All-virtual compared with in-person | −0.18 | −0.29, -0.07 | 0.001
All-virtual compared with hybrid | −0.17 | −0.22, -0.12 | <0.001
Therapists: felt confident in education
Hybrid compared with in-person | −0.005 | −0.08, 0.07 | 0.90
All-virtual compared with in-person | −0.10 | −0.14, -0.06 | <0.001
All-virtual compared with hybrid | −0.09 | −0.14, -0.05 | <0.001
Physicians: felt confident in quality of care
Hybrid compared with in-person | −0.002 | −0.03, 0.02 | 0.88
All-virtual compared with in-person | −0.19 | −0.21, -0.17 | <0.001
All-virtual compared with hybrid | −0.19 | −0.21, -0.16 | <0.001
Physicians: felt confident in education
Hybrid compared with in-person | −0.005 | −0.02, 0.01 | 0.62
All-virtual compared with in-person | −0.10 | −0.12, -0.08 | <0.001
All-virtual compared with hybrid | −0.10 | −0.12, -0.08 | <0.001
Physicians: felt confident in physical exam
Hybrid compared with in-person | −0.009 | −0.05, 0.03 | 0.66
All-virtual compared with in-person | −0.41 | −0.46, -0.37 | <0.001
All-virtual compared with hybrid | −0.40 | −0.45, -0.36 | <0.001

Table 3 Integrated Results Matrix

Domain | Quantitative result summary | Qualitative result summary | Meta-inferences
Parent experience | No difference in parent experience scores between in-person and hybrid models | While parents would prefer an in-person visit, they believe the hybrid model to be of high quality. “My daughter has very unique anatomy, and there’s some hands-on that helps her appointment but our therapists we’re very seasoned with so she’s able to explain to the doctor very technically what she’s capable of and the different ranges of motion.” | Parents’ regard for providers remains high regardless of the model of care. Parents perceive the all-virtual model as significantly lower quality but recognize their necessity when in-person visits are not feasible. The hybrid model is an acceptable alternative to traditional in-person visits.
Parent experience | No difference in parent experience scores for all-virtual model compared to hybrid and in-person models | Parents found the all-virtual visits to be lower quality but appreciate having continued care during the pandemic and have high regard for the care team. “I’ll take the video right now during COVID instead of not having the doctor’s appointment.”
Therapist-reported quality of care | No difference in therapist-reported confidence in quality between in-person and hybrid models | Therapists who used the hybrid model believed these visits were high quality, particularly after some training and practice. “We got into the groove of the telehealth, started really liking it, and then the pandemic hit.” | Therapists perceived the hybrid model as a high-quality alternative to traditional in-person visits, particularly after training and experience using the model. The nature of physical and occupational therapy often does not lend itself to an all-virtual visit.
Therapist-reported quality of care | Significantly lower therapist confidence in quality for all-virtual visits | Therapists reported that many visits were low quality due to technical issues, distractions, difficulty engaging with the patient, and parents’ inability to position the child. “There are just limitations with the telehealth visits. If they are higher functioning and can follow directions and are engaged and aren’t shy it goes well but you still can’t feel the tone or anything.”
Therapist-reported quality of care | No difference in therapist-reported confidence in parent education on the care plan between in-person and hybrid models | Because therapists are in person with patients during hybrid visits, they can ensure that parents are educated on the continuing care plan. “In-person visits are better for hands-on manual-based therapies like showing the parents how to do a stretch or an activity.” | Parents are often managing other children and responsibilities during virtual visits, and may encounter technical issues that cause distractions during the visit. Demonstrating exercises or stretches over video is also difficult, and may results in lower parental understanding of the continued care plan. The hybrid model still offers the opportunity for high-quality education through physical demonstration to parents.
Therapist-reported quality of care | Significantly lower therapist confidence in parent education on the care plan for all-virtual visits | Therapists perceive that parents are often distracted during all-virtual visits and may not take in as much information as in-person. “I think sometimes they’re not really thinking this is a real doctor’s appointment because they’re not there.”
Physician-reported quality of care | No difference in physician-reported confidence in quality between in-person and hybrid models | Physicians had high confidence in the therapists’ ability to conduct the exam during the hybrid visits. “Most of the therapists that I’ve worked with, we can get on the same page and I feel confident in my decisions as a result of the data they give me.” | Physicians perceive the hybrid model as a high-quality, acceptable alternative to in-person visits. While all-virtual care was perceived as providing some benefits to patients and providers, the quality of the visit was seen overall as low and should be used only in certain circumstances.
Physician-reported quality of care | Significantly lower physician confidence in quality for all-virtual visits | Physicians expressed that something was lacking in all-virtual visits and were often uneasy not having a proper exam by a physician or therapist. “There are some benefits but for me the lack of physical exam, the data that I gather and how I’m making my decisions, I’m much more comfortable with someone laying hands upon the child, looking at that equipment, being present.”
Physician-reported quality of care | No difference in physician-reported confidence in parent education on the care plan between in-person and hybrid models | The hybrid and in-person models both involve the parents being present in person, which provides a better opportunity for education about the care plan due to fewer distractions and technical issues. “There is a little less chaos when they are in the therapy unit.” | Distractions and other limitations of all-virtual visits may inhibit the physiatrists’ ability to effectively communicate with parents about the patient’s continuing care plan. The hybrid model does not pose this difficulty, since the therapist is present and the parent and child are physically in a quiet space in the medical therapy unit, where they can be more engaged during the visit.
Physician-reported quality of care | Significantly lower physician confidence in parent education on the care plan for all-virtual visits | All-virtual visits often have many distractions that can lower the quality of communication between physicians and patients. “I’ve had many where the kids are in the parking lot in the parent’s car. They don’t have their braces on, you’re asking can I see your braces, and saying where are you, is it safe to get out and walk where you are?”
Physician-reported quality of care | No difference in physician-reported confidence in physical exam between in-person and hybrid models | Physicians trained therapists to conduct the physical exam and have confidence in their ability to assess the patient. “I think if the therapist is there, it’s fine, they’re able to stretch them and give me an idea of whether they need to be casted or not.” | Although there are some circumstances in which physicians prefer to examine a child themselves, physicians generally trust the therapist to conduct the physical exam and relay key information over video using the hybrid model. In contrast, physical exams during all-virtual visits often provide little value.
Physician-reported quality of care | Significantly lower physician confidence in physical exam for all-virtual visits | Physicians found it difficult to assess children over video with support from only the parent. “When we see them in person, we’re picking up on all these little changes and nuances that are occurring, little subtle changes, and you can’t always see that through telehealth.”

## Appendix A

Map showing how counties have varying types and numbers of physicians, making MTU availability differing among counties in California.

## Appendix B

Sample Parent/Gaurdian Survey including Parent/Gaurdian consent disclosure and questions to be answered by the Parent/Gaurdian. The questions used helped determine perceptions of quality of care using telehealth.

## Appendix C

Sample satisfaction survey physiatrists and therapists were requested to complete within 48 hours of a patient encounter including questions with a sliding scale ranging from Strongly Disagree to Strongly Agree

## LIST OF PUBLICATIONS AND PRODUCTS

### Presentations

“School-Based Tele-Physiatry Assistance for Rehabilitative and Therapeutic Services (STARS) for Children with Special Health Care Needs Living in Rural and Underserved Communities.” Presentation to Child Care Services – Department of Healthcare Services (CA), March, 2019.

“CCS Medical Therapy Program via Telemedicine” Presentation to the American Academy for Cerebral Palsy and Developmental Medicine 73^rd^ Annual Meeting, Anaheim, CA, September, 2019.

“Parent and therapist experience with a novel tele-physiatry program for children living in rural and underserved communities” Presentation to the National Telehealth Research Symposium 2021. Virtual, November 2021.

### Posters

Amanda Favila-Meza. Using Telehealth to Support California’s Medical Therapy Program Serving Children with Disabilities. Poster presentation at the National Telehealth Research Symposium 2019, Chicago, IL September 19, 2019

Amanda Favila-Meza. Supporting California’s Medical Therapy Program Serving Children with Disabilities through Telemedicine. Poster presentation at the Western Medical Research Conference 2020, Carmel, CA, January 23, 2020

Amanda Favila-Meza. Telemedicine: A Means of Delivering Care to California’s Medical Therapy Program Serving Children with Disabilities. Poster presentation at the UCSF Annual Health Services Research Colloquium May 2020, San Francisco, CA, May, 2020

### Manuscripts

Davidson L, Haynes SC, Favila-Meza A, Hoch JS, Tancredi DJ, Bares AD, Mouzoon J, Marcin JP. Parent Experience and Cost Savings Associated With a Novel Tele-physiatry Program for Children Living in Rural and Underserved Communities. Arch Phys Med Rehabil. 2022 Jan;103(1):8–13. doi: 10.1016/j.apmr.2021.07.807. Epub 2021 Aug 21. PMID: 34425088.34425088

Lee T, White AA, Payne TH. Effects of a portable voice recognition system on hospital medicine professional fee billing. Manuscript in preparation.

## REFERENCES

1 Olson CA, McSwain SD, Curfman AL, Chuo J. The current pediatric telehealth landscape. Pediatrics 2018;141:e20172334.29487164
2 Marcin JP, Rimsza ME, Moskowitz WB. The use of telemedicine to address access and physician workforce shortages. Pediatrics 2015;136:202–9.26122802
3 Marcin JP, Ellis J, Mawis R, Nagrampa E, Nesbitt TS, Dimand RJ. Using telemedicine to provide pediatric subspecialty care to children with special health care needs in an underserved rural community. Pediatrics 2004;113(1 Pt 1):1–6.14702439
4 Hagglund M, Scandurra I, Koch S. Integrated care plan for shared home care: the technical architecture. J Inform Technol Healthcare 2005;3:287–94.
5 Consumer Assessment of Healthcare Providers and Systems (CAHPS) Survey. Agency for Healthcare Research and Quality.
6 Stata Statistical Software: Release 17. StataCorp LLC; 2021.
7 Glaser BG. The constant comparative method of qualitative analysis. Social problems. 1965;12(4):436–445.
8 Sukhov R, Asante A, Ilizarov G. Telemedicine for pediatric physiatry: How social distancing can bring physicians and families closer together. Journal of Pediatric Rehabilitation Medicine. 2020;13:329–338. doi:10.3233/PRM-200747.33104050