# Diabetes and Depression Text Messaging Intervention (DIAMANTE)

AHRQ Grant Final Progress Report

## Purpose

The main aim of the ‘Diabetes and Mental Health Adaptive Notification Tracking and Evaluation’ trial (DIAMANTE) was to test a smartphone intervention that generated adaptive messaging, learning from daily patient data to personalize the timing and type of text messages. We compared the adaptive content to (1) a uniform random messaging intervention, in which the messaging content and timing will be delivered with equal probabilities (ie, not adapted by a learning algorithm), (2) a control condition that only delivers a weekly mood message. The primary outcomes for this aim will be improvements in physical activity at 6-month follow-up defined by daily step counts.

We investigated the following specific aims in the study:

Aim 1: Conduct user testing of the DIAMANTE platform in English and Spanish.

We conducted three iterative phases of User Centered Design (UCD) testing with ten patients each (n=30).

The goal of the first UCD phase was to identify key messages that will motivate physical activity behavior change for diverse patient populations. Patients participated in 1.5 hour individual semi-structured interviews to identify barriers and facilitators to physical activity. They participated in a card sorting activity and provided feedback on messages they liked, those they disliked, and those they were neutral towards. Findings from phase 1 were used to inform content and information delivery decisions of the final intervention including selecting the thematic message categories and the design decisions.

The second phase UCD aimed to evaluate the perceived ease of use and usefulness according to the Technology Acceptance Model (TAM), as these are two key determinants of eventual use of a technological system. In this phase, patients participated in receiving text messages for 2-weeks and providing feedback on the text messages and on their participation in the program.

In the third phase of UCD, patients received the entire platform for an “in the wild” evaluation for a 2-week period. Data collected during this phase was used for the reinforcement learning algorithm to begin “training”. After this brief initial collection of data, the algorithm began sending individual messages that took into consideration previous outcomes. Patients were contacted after 1 week throughout this evaluation and completed an interview that addresses components of the TAM as well as usability. Additionally, we met with 3 groups consisting of 2 to 3 clinicians to obtain feedback on the DIAMANTE intervention. We showed clinicians the existing website and dashboard as well as mock-ups and low fidelity prototypes of future iterations.

The third phase tested out the final DIAMANTE intervention including thematic message content and finalized application in order to address any user-related issues prior to launching the randomized control trial (see figure 1 for an overview of the different UCD phases and the RCT).

Figure 1 Overview of difference phases DIAMANTE

Overview user-centered design process (UCD) and randomized trial. We first conducted three iterative phases of only UCD with 10 patients each (total n=30). The Diabetes and Mental Health Adaptive Notification Tracking and Evaluation trial will have different intervention groups: adaptive (n=92), static (n=92) and control (n=92). RCT, randomized controlled trial.

Aim 2: Evaluate the effectiveness of adaptive vs. static messaging intervention. The first goal of the randomized trial was to study the influence of personalized text messaging on both glycemic control and depressive symptoms. For the randomized trial, we recruited 196 adults from primary care clinics within the San Francisco Health Network and through social media recruitment.

During the randomized control trial we investigated the following hypothesis:

Primary hypothesis: We expected that the group receiving adaptive messaging had a statistically significant higher increase in step counts over the 6-month intervention period, compared with both the group receiving the uniform random messaging and the control group receiving only a weekly mood message. We expected that both the adaptive and the uniform random messaging groups had a higher increase in step counts than the control group.

Secondary hypotheses

● We expected that the group receiving adaptive, personalized messages had a significant reduction in hemoglobin A1c (HbA1c) levels, depression scores, weekly mood ratings, higher behavioral activation, lower rumination and anxiety, more positive attitudes about PA and higher self-efficacy to manage chronic diseases at 6 months, compared with the group that received the uniform random messaging intervention and the control group.
● Exploratory: because of the unique nature of the patient population enrolled in our study, we expected to find differences by language (English vs Spanish). Language has been shown to be especially influential in mobile technology uptake and effectiveness in our previous work.^1^ Spanish speakers may engage more in the mobile intervention and might have different motivations for becoming physically active, which might result in differences in effectiveness of the various messages.

Aim 3: Evaluate the effectiveness of phone outreach for non-responsive participants. The secondary goal of the trial is to evaluate the influence of phone outreach on glycemic control and depressive symptoms for participants who are non-responsive to the text messaging approaches used in this study.

## Scope

### Background

Both depression and diabetes are highly prevalent, often co-occurring diseases that are among the major causes of global disability.^2–4^ Comorbid diabetes and depression are associated with a worse prognosis of both diseases, including a higher rate of complications of diabetes, greater disability and an increased risk of mortality.^5^ Vulnerable populations, including low-income, low health literacy and ethnic minority individuals experience higher prevalences and worse outcomes for both diabetes and depression.^6^ ^7^ There is a great need for the development of treatments that can target overlapping risk factors for diabetes and depression. A growing body of evidence suggests that physical activity (PA) is such a risk factor: it is linked to both mental health and diabetic outcomes.^8–12^

Mobile applications have been found effective in helping patients engage in healthy behaviors including PA. For instance, a recent meta-analysis of nine RCTs concluded that smartphone apps that focus on PA have a moderate positive effect on increasing PA levels, and another meta-analysis including 18 studies moderate-to-large effect in daily step changes.^13^ ^14^ These effect sizes are similar to ‘face-to-face’ interventions.^15^ However, because around 70% of lower income Americans (including Latinos) currently own smartphones,^16^ and the ownership of smartphones is expected to increase in low-income populations globally,^17^ mobile apps have great potential to reach individuals that normally do not have access to care. Further, mobile technology can help overcome existing barriers in access to care for vulnerable populations, including lower availability of psychological treatment in primary care settings, language and literacy barriers, stigma, cost and inflexible employment schedules.^18^ Latinos in the USA in particular show higher underutilization rates of mental health treatment than non-Latino whites.^19^ Deploying effective mobile applications can therefore decrease existing decrease disparities in health.

However, in the US, low-income minority patients frequently receive their care in safety net settings (services in the public sector for those unable to attain private health insurance), where novel mobile technologies are not often designed, developed or implemented.^20^ This translational gap increases the probability that these interventions will ultimately fail when implemented in actual clinical settings that serve vulnerable populations.

Further, most mobile applications that target behavioral changes are not personalized,^21^ which could contribute to lower effect sizes of these interventions for trials with longer study durations (e.g., over 3 months).^13^ Smartphone interventions allow for data collection by passive sensing technologies, which offer an opportunity for tailoring and personalizing interventions to users’ behaviors, preferences and needs. Personalization can be achieved by computer tailoring: tailoring interventions to observed behavior and characteristics of the participant. This can include feedback, goal setting or user targeting (i.e., conveying that communication is designed specifically for the user).^22^ However, more complex forms of personalization might be needed to increase and maintain engagement with PA interventions,^23^ a requirement for a digital intervention to be effective.

One promising approach is to use adaptive learning, which allows the prediction of which content might be effective for users, learning from its previous actions and participant data collected by mobile phones.^24^ For instance, an adaptive learning algorithm might be more effective as it can match motivation needs for each participant. Some intervention studies have attempted cultural tailoring to large groups of people. However, most tailoring approaches occur at the group level whereas we are bringing the tailoring down to the individual level.^25^ Research on the efficacy of these adaptive treatments is still in its early stages.

### Population

Patients were recruited within Zuckerberg San Francisco General hospital (ZSFG) and various clinics, including the Richard Fine People’s Clinic, the Family Health Center, in the San Francisco Health Network which is operated by the Department of Public Health in San Francisco, California that served as the study sites for this trial. Several clinicians and endocrinologist providers at ZSFG helped identify patients. These clinics serve a diverse, chronically ill population and, as in many public hospital settings, they employ multiple part-time providers, creating the risk for lack of continuity of care that mobile health programs may be able to supplement. Social media and online recruitment methods were added in December 2020 as a result of recruitment complications due to COVID-19. Ads targeted various cities within the United States.

### Inclusion criteria

Patients aged 18–75 years who have been diagnosed with diabetes and documented depression and/or depressive symptoms with a score >5 on the PHQ-9, as determined by their medical health records, were eligible for this study. Eligible patients needed to use text messaging and have an iPhone or Android smartphone in order to download the pedometer app onto their phones, but they did not need to be proficient in using mobile phone applications. Concomitant care and interventions were permitted during the trial.

### Exclusion criteria

We excluded patients with: an inability to exercise due to physical disability; active psychosis or mania; active suicidal ideation; severe cognitive impairment; inability to read and write in English or Spanish; current pregnancy; planned to leave the country for extended periods of time during the 6-month trial.

## Methods

### Design

This study is a randomized, controlled trial with three groups and a primary endpoint of increase in daily number of steps during a 6-month intervention delivered by a smartphone app. Randomization was performed as block randomization with a 1:1:1 allocation. Patients were automatically randomized into groups through our secure server during onboarding of the app, thereby ensuring allocation concealment. Patients were informed of the nature and frequency of the messages they would be receiving and were allowed to discuss this with investigators during the course of the study. Further, if messages were not being sent out appropriately, research assistants contacted the app developer to address errors within 24 hours. If PA data did not come in, research assistants contacted participants to ensure that the app was actively running on their phone, and assisted participants with redownloading the app if necessary. The necessity of these steps made it unfeasible to blind the researchers. We used the Standard Protocol Items: Recommendations for Interventional Trials checklist when writing our report.

### Recruitment

Patients were recruited by direct provider referrals, in-person clinic recruitment timed to eligible patient visits and through social media advertisements. To identify potentially eligible patients, we asked for permission from known providers to pull patient lists, and review and identify patients with diagnosis of diabetes and depression that fit our inclusion criteria (e.g., is able to walk and is not pregnant).

### Baseline visit

A researcher asked patients if they are interested in joining a study to increase PA and help manage their mood using their mobile phone. Interested individuals were invited into our offices at ZSFG for a baseline study visit and to obtain informed consent in Spanish or English. Thereafter, we collected all baseline survey measures of interests as well as patient demographics and information about current mobile technology familiarity and utilization. All patients received assistance in downloading a pedometer application onto their phone and sent test text messages back to our system. The researcher constructed a plan for PA goals with the patient and instructed patients to have the app open at all times. Thereafter, users were automatically randomized by the secure server, using a block randomization with block size 3 to allocate individuals into either the uniform random, adaptive or control group.

### Partial patient and public involvement

Patients worked with us to design the text messages, mobile app user interface and were asked to assess the burden and time commitment of the study, as part of our user-centered design approach. We did not involve patients in other areas of the study design.

### Measures

Our primary outcome, change in daily step counts, was passively collected by a mobile phone application during the time that patients remain in the intervention. For secondary outcomes, we derived HbA1c, the average plasma glucose over the previous eight to 12 weeks, recommended as a means to diagnose diabetes,^26^ from patients’ electronic health records (EHR). We used the most recent, available measurement from a maximum of 12 months before participating in the study. After 6 months, we again assessed the most recent HbA1c (pulling from patients’ EHR), ensuring that at least 3 months elapsed between baseline and follow-up HbA1c levels. For additional secondary outcomes, we administered a survey at baseline and 6-month follow-up.

The project coordinator and research assistants were responsible for managing patient data collection. Data was stored on UCSF Qualtrics and the HealthySMS platform. Once data from all patients are collected, it will be stored on UCSF’s Secure Box, a secure cloud-hosted platform.

### Engagement measures

In addition to PA and the measures mentioned above, we also examined engagement measures, such as (1) times that the app was opened (2) time spent reading the messages (3) usability data, assessed by the Systems Usability Scale^27^ and open-ended qualitative questions about their opinions of the app.

### Interventions

We employed a mobile phone app, ‘DIAMANTE’ developed by Audacious Software (https://diamante.healthysms.org/). This application tracks step counts by pooling from Google Fit, Apple HealthKit or the built-in pedometer on patients’ phones. We used a text-messaging platform HealthySMS, previously developed by Dr. Aguilera and Audacious Software, to send text messages and manage patient responses back to our system. The app only needed to be installed once, but had to remain open consistently. The app is designed in English and Spanish versions and is freely available as a download from the Apple App Store and Android Google Play application.

Figure 1 shows the different intervention groups during the trial period. Briefly, both the adaptive and uniform random group received the same types of messages: feedback (four active categories plus no message) and motivation (three active categories plus no message). However, the message categories, timing and frequency were optimized by a reinforcement learning (RL) algorithm in the adaptive group, and were delivered with equal probabilities in the uniform random group (following a uniform random distribution). The control group did not receive these messages (only a weekly mood check-in message). All groups had the app downloaded on their phone and their steps were passively tracked within the app. See figure 1 for an overview.

#### Control condition

Control patients only installed the app on their phone and did not receive any feedback messages. They received one message a week, on a fixed day, asking them to assess their mood in the previous week on a scale of 1–9. The message was sent weekly at 10:00. Non-responders received reminders to submit their mood self-assessments in 2 hours intervals.

#### Uniform random message arm

We sent patients up to two messages per day within four randomly selected time intervals. These messages are based on the COM-B framework (examples shown in table 1A,B). In addition, they received one message, on the seventh day, which asked patients to rate their mood on a scale from 1 to 9. PA (step-count/day) was passively monitored via the app on their smartphone.

Table 1 Daily motivational and feedback messages DIAMANTE study

A Different categories with feedback messages that the algorithm chooses from

Feedback messages | Examples
0. No feedback message
1. Reaching goal | “Yesterday, you did not reach you goal”
2. Steps walked yesterday | “Yesterday, you walked 3828 steps”
3. Walked more/less today than yesterday | “Yesterday, you walked more you’re your goal”
4. Steps walked yesterday, plus a positive/negative motivational message | “You walked 8000 steps yesterday. Great job!”

B Different categories with Motivational messages that the algorithm chooses from

Motivational messages | Examples
0. No message
1. Capacity, describes the physical and psychological benefits of walking and exercise | “Doing more physical activity can help reduce feelings of fatigue”
2. Motivation, meant to increase self-confidence and the belief that one is capable of walking even in the face of challenges | “You have made changes to improve your health before, you can do it again”
3. Opportunity, physical and social environment cues that make it more likely to engage in walking | “It there a local park you have been waiting to visit? Use it as an opportunity to get out of the house and do more steps?”

The algorithm can also choose not to send a message (category no feedback).

The algorithm can also choose not to send a message (category no motivation).

#### Adaptive message arm

Patients in the adaptive messaging arm received the daily COM-B messages (equal to the uniform random arm, examples shown in Table 1A,B), but the message categories, timing and frequency, were not chosen randomly, but by using an RL algorithm. This allowed us to adequately assess whether differences in effects are driven by the use of the RL algorithm. In addition, they received one message, on the seventh day, which asked patients to rate their mood on a scale from 1 to 9. PA (step-count/day) was actively monitored via the app on their smartphone.

Patients in all groups received reminders to open the app if no data are being transmitted. Additionally, patients in all groups could reply ‘STOP’ or ‘PARAR’ if they wished to stop receiving messages. Finally, the researchers monitored the incoming step data. The researchers contacted the patients by phone for troubleshooting if patients’ phones were not transmitting data for more than 3 days.

#### Adaptive learning algorithm

We developed an RL algorithm (an area of machine learning) based on previous work.^28^ On a daily basis, this algorithm assessed (1) which feedback message (Table 1A), (2) which motivational message (Table 1B) and (3) which time period of the day (in intervals of 2.5 hours from 09:00 to 19:00) is predicted to maximize the number of steps walked the next day. We used algorithms for contextual multi armed bandit (MAB) problems, as these have been employed in different domains (including mobile health) and show promise to maximize cumulative rewards in sequential decision tasks (here, which sequences of messages optimally promote PA).^29^ A contextual MAB problem is an RL setting in which the algorithm chooses between different treatment options which all have different reward functions. The reward functions depend on contextual variables.

We used Thompson Sampling, a Bayesian method, which allowed us to continuously learn which feedback and motivational messages were effective for a user, based on contextual features like their previous PA, demographic and clinical characteristics (such as age, gender and PHQ-8 scores). Thompson sampling effectively dealt with small amounts of data and addressed the exploration/exploitation tradeoff.^30^ As such, it frequently picked out from the most rewarding messages and occasionally explored the messages with uncertainty in their reward.

More specifically, each morning, the algorithm evaluated which messages would likely increase the PA for every participant in the upcoming day, and at which time period the messages should be delivered. The algorithm training data consisted of the historical data of all participants (contextual variables), which included which messages were sent previously and within which time periods, and select clinical/demographic data (such as age, language and depression scores) to improve prediction abilities.

During the trial, patients received messages for 6 months. After 6 months, provided patients the possibility to remain receiving messages for up to 9 months.

## Results

### SA - 1 User Centered Design

We completed the UCD in Aim 1 by the second year of the grant and published two manuscripts. Our application was “live” in both the App Store and Google Play for download. A manuscript on the design process, given that we were able to use participant feedback, crowdsourced data from mTurk, and health behavior theory to finalize the text-messages in English and Spanish for our RCT.

### SA 2 - Randomized control trial

We also published our RCT study results in JMIR (https://www.jmir.org/2024/1/e60834). The manuscript provides a detailed account of the hypotheses, rationale, and methodology, and results of the study. Here is a summary of the key findings:

The research team recruited a total of 195 participants into the RCT between January 2020-June 2022. The CONSORT diagram is shown in Figure 1. A total of 13 participants were dropped by the researchers due not installing or immediately deleting the DIAMANTE App, and another 14 were excluded because of insufficient (n=9) or incorrect (n=5) step count data explained above. The final analytical sample included 168 participants, each of them are observed 168 days. Over one-third of participants were recruited from the San Francisco Health Network (n = 63, 37.5%) and the remaining recruited online (n = 105, 62.5%). Baseline demographic characteristics stratified by the intervention arm are reported in Table 2. Overall, the sample participants were middle-aged (age mean = 49 years), predominantly female (62%), and majority English speakers (76%). The sample was diverse in terms of race/ethnicity, education, and employment status. Finally, due to data transmission errors (e.g., not having the app open) there was an average of 20 missing days of step data (SD = 32.72) for study participants, and the average step count within the sample was 3221 steps at baseline and 3783 at follow-up. By arm, participants in the Control arm had an average of 3701 steps (SD = 3054.53) on Day 1 of the intervention and an average of 26 days of missing data (SD = 36.91), participants in the Random arm had an average of 3471 steps on Day 1 (SD = 3274.78) and an average of 20 days of missing data (SD = 32.54). Lastly, adaptive arm participants had an average of 2277 steps on Day 1 (SD = 2250.87) and an average of 14 days of missing data (SD = 27.2).

Table 2 Baseline Demographics

| Control; n = 57 | Random; n = 56 | Adaptive; n = 55 | Total; N = 168
Age in years, Mean (SD) | 51 (13.2) | 49 (11.0) | 48 (12.1) | 49 (12.1)
Gender, n (%)
Female | 35 (61%) | 38 (68%) | 31 (56%) | 104 (62%)
Male | 20 (35%) | 18 (32%) | 23 (42%) | 61 (36%)
Language, n (%)
English | 42 (74%) | 44 (79%) | 42 (76%) | 128 (76%)
Spanish | 15 (26%) | 12 (21%) | 13 (24%) | 40 (24%)
Race/Ethnicity, n (%)
Asian or Pacific Islander | 4 (7%) | 4 (7%) | 4 (7%) | 12 (7%)
Black or African American | 11 (19%) | 9 (16%) | 7 (13%) | 27 (16%)
White or Caucasian | 14 (25%) | 17 (30%) | 19 (34%) | 50 (30%)
Latinx or Hispanic | 22 (39%) | 20 (36%) | 22 (40%) | 64 (38%)
Multi-Racial/Ethnic | 6 (11%) | 6 (11%) | 3 (6%) | 15 (9%)
Education, n (%)
Some high school or less | 11 (19%) | 10 (18%) | 8 (14%) | 29 (17%)
High school graduate | 7 (12%) | 8 (14%) | 9 (16%) | 24 (14%)
Some college or technical school | 9 (16%) | 17 (30%) | 18 (33%) | 44 (26%)
College graduate | 24 (42%) | 16 (29%) | 15 (27%) | 55 (33%)
Graduate degree | 6 (11%) | 5 (9%) | 5 (9%) | 16 (10%)
Employment, n (%)
Full time (> 35 hours/week) | 19 (33%) | 19 (34%) | 22 (40%) | 60 (36%)
Part-time (< 35 hours/week) | 9 (16%) | 15 (27%) | 5 (9%) | 29 (17%)
Homemaker | 2 (4%) | 3 (5%) | 6 (11%) | 11 (6%)
Unemployed | 8 (14%) | 9 (16%) | 10 (18%) | 27 (16%)
Disabled /on disability | 11 (19%) | 6 (11%) | 10 (18%) | 27 (16%)
Retired | 7 (12%) | 4 (7%) | 1 (2%) | 12 (7%)
Depression scores
PHQ-8 (SD) | 10.23 (6.54) | 12.0 (6.67) | 10.42 (6.0) | 10.88 (6.42)

The results of the primary linear effect mixed model are presented in Table 3. The results indicate that on average at the start of the intervention participants in the Adaptive group had 3197 steps, the Control group had 3480, and Random had 3698. The random intercept effects were estimated at 5419080.25 (SD = 2237.39) indicating a large amount of variability in step count between participants. There were no statistically significant differences in baseline step count between intervention groups. For the adaptive group there was a significant daily step increase of 3.6 steps (P<.001); estimating at 168 days of the intervention, participants in the adaptive group would have gained an average of 606 steps indicating a 19% increase in daily step count. The Control (P=.001) and Random group (P<.001) had statistically significantly lower rates of change (albeit positive) in daily step count relative to Adaptive group. The Control group increased linearly by .81 steps per day for a total of 136 steps or an increase of 3.9% daily steps from day 1 to day 168 of the intervention. Finally, the Random group increased linearly by .35 steps per day for a total of 59 steps per day indicating an increase of 1.6% daily steps from day 1 to day 168 of the intervention (Figure 2).

Table 3 Linear Mixed Model Daily Step Count

Parameter | Estimate | Lower 95% CI | Upper 95% CI | P-value
Intercept (Adaptive) | 3196.79 | 2568.03 | 3825.54 | <.001
Control | 283.32 | −598.67 | 1165.32 | 0.531
Random | 500.92 | −384.54 | 1386.36 | 0.271
Day-1 | 3.61 | 2.45 | 4.78 | <.001
Control´(Day-1) | −2.80 | −4.47 | −1.13 | .001
Random´(Day-1) | −3.26 | −4.92 | −1.60 | <.001

Figure 2 Linear Trajectory of Step Count over 168 days of study

Linear graph showing an increase for adaptive, random and control arms, as described in paragraph above.

Based on our a priori sub-analysis, the LMM results indicated statistically significant positive rates of change in daily step count for Adaptive group participants in both the SFHN sub-sample (average baseline steps 3278, daily rate of change 6.0 steps (P<.001), 30.6% increase in daily step count post intervention) and the online sub-sample (average baseline steps 3156, daily rate of change 2.3 steps (P=.002), 12.2% increase in daily step count post intervention). These results were in line with the overall analysis. However, in the SFHN sample the daily steps rate of change for the Random and Control groups were statistically significantly different and negative relative to the Adaptive group. Whereas for the online sample the daily rate of change for both the Random and Control groups were positive but not statistically significantly different than that of the adaptive group.

### Reinforcement learning model

We developed another scientific paper detailing the scientific decisions encountered when finalizing our reinforcement learning algorithm used in this study. This was published in JAMIA in February 2021: https://pubmed.ncbi.nlm.nih.gov/33657217/. In summary, our final reinforcement learning algorithm personalized feedback and motivational text messages to send for the adaptive arm of our RCT. On a daily basis, this algorithm assesses 1) which feedback message, 2) which motivational message, and 3) which time period of the day (in intervals of 2.5 hours from 9am to 7pm) is predicted to maximize the number of steps walked the next day.

### Recruitment

We recruited San Francisco Health Network patients from an active list of over 600 patients with diabetes and depression that speak English or Spanish, and over 40 providers review their own patients from this list to facilitate our study recruitment.

During the second week of February 2020, our research staff began to actively recruit patients to participate in the randomized trial, using detailed verification of eligibility criteria and meticulous training of all research assistants. We recruited a total of 15 participants during the first four weeks of in-person RCT recruitment prior to the COVID pandemic.

We then had to pause recruitment after the COVID-19 social distancing orders in the California Bay Area in early March of 2020, and get IRB approval to switch all recruitment steps to remote processes via phone and Zoom. This process was challenging given the digital literacy barriers of our patient population, who were no longer able to receive our in-person assistance with downloading our DIAMANTE app onto their smartphones. To circumvent these challenges, we reformatted all onboarding processes to add remote assistance for our patients in learning to use Zoom and download apps onto their smartphones themselves. We also created a new recruitment protocol to emphasize one-on-one staff-patient partnerships to provide this specialized technical assistance personalized to each patient’s digital skills. Using research staff’s expertise and training, along with patient insight, we increased access to the intervention and created the infrastructure to offer technical assistance.

The adaptation of previous in-person study procedures to remote practices took place from March to April 2020. As an initial step, we analyzed the digital profiles—including digital literacy and device or broadband access—of patients who participated in our previous pre–COVID-19 in-person sessions (hereafter referred to as the pre–COVID-19 cohort). Following the analysis, research staff met to discuss personal experiences encountered during previous in-person onboarding sessions. Analysis and feedback allowed us to address the most relevant barriers to and facilitators of an internet-based remote visit. The results led us to alter our study procedures to orient patients to download the digital health application being studied via an internet-based remote visit (i.e., by using the Zoom video conferencing software or during a phone call). The project coordinator conducted several educational meetings to introduce and share the rough outlines of the new study procedures with the entire research team. Several amendments were made to these outlines based on onboarding research staff’s feedback and internal piloting efforts.

The final versions were then used to enroll eligible patients into a complete, digitized version of the clinical trial during the period of social distancing in the context of the COVID-19 pandemic (hereafter referred to as the COVID-19 cohort), from April 2020 to June 2021. Enrolled patients who were able to attend a remote onboarding visit were asked about the new remote recruitment processes, and their feedback was both audio-recorded and documented with detailed field notes. Following California’s lift of all stay-at-home orders in June 2021, along with changes in university policies that allowed for in-person research activities. We offered a hybrid model, where patients could choose to complete in-person and/ or remote enrollment. This also allowed research staff to recruit from clinics in-person.

Finally, in December 2020, we added additional online-only recruitment methods that allow for the self-enrollment of eligible participants that meet our existing DIAMANTE study criteria. Using Craigslist, Facebook, Google Ads we were able to enroll 125 additional participants nationwide. Our final recruitment totals for the DIAMANTE RCT, combining SFHN patients and online participants, is n=197.

### Discussion

Our study found that applying a reinforcement learning algorithm for personalizing text messaging interventions is an effective approach for increasing physical activity in a diverse sample of people with diabetes and depression. We found significant step count increases over 6 months (168 days) in the adaptive, reinforcement learning intervention arm, as compared to participants that received randomly selected text message content (random messaging arm) or only a weekly mood self-monitoring message (control arm). We found that reinforcement learning algorithms can increase the effectiveness of a physical activity based digital health intervention in a diverse, real-world sample with comorbid diabetes and depression symptoms. Our findings are particularly significant because most digital health studies in vulnerable populations to date have been pilot studies, and the use of machine learning methods for personalization is rarely applied to low-income and Spanish speaking populations. These findings also support previous studies using a similar reinforcement learning algorithms.

### Decreasing health disparities

Though the numbers of mHealth pilot studies are increasing in vulnerable populations, many of these fail to follow through with an implementation component to the study design.^31^ Here, we used a blended design: while the intervention is in addition to current care, there are ways we are attempting to make it more a part of patients’ clinical care. For instance, patients are mainly approached through primary care health providers, which recommend eligible patients whom they think are directly interested in a PA intervention. In addition, we will make patients’ data available to providers: a summary of the step increase for that patient at the conclusion of the study and updated PHQ-8 and GAD scores entered into the record. Our study therefore is the first step to addressing this gap because of its integration in primary care clinics that serve low-income patients. Future work should focus more specifically on implementation of the app as part of routine clinical care.

### PA measure

We chose passively collected daily step count from patients’ preowned digital devices as a measure of PA. Although there are many different ways to measure PA, daily step count seems to be a particularly relevant measure because of: (1) its relative ease to measure, and (2) the clinical importance of individuals’ walking behavior. Low number of daily step counts have been associated with all-cause mortality in some longitudinal studies^32^ and results from pooled population studies show clear dose–response effects of PA to overall mortality.^33^ In patients with type 2 diabetes, several studies have now shown that increasing step counts can significantly decrease HbA1c levels. For instance, a 10 000 steps per day walking prescription increased steps and decreased HbA1c in patients with type 2 diabetes.^34^ Further, Manjoo et al found that each SD increase in daily steps was associated with a 0.21% decrease in HbA1c.^35^ However, negative findings have also been reported. For instance, a meta-analysis by Qiu et al found that step-counter use was associated with increased steps per day (over 1800 more steps compared with a control group) among people with diabetes, but not with lowering of HbA1c.^36^

In exploratory post hoc analyses, we will also be able to examine the more immediate effect of PA messages, for example, on hourly steps in addition to daily steps, which will help to improve future PA interventions (e.g., deliver messages at the right times). For instance, it is possible that one could receive a message in the morning and make plans to walk in the afternoon or evening, or messages could have more of an immediate impact. This information is currently unknown.

### Personalization of intervention

The results of this RCT will help us understand if adaptive mHealth interventions for depression and diabetes are more beneficial than interventions that do not use learning algorithms. If mHealth interventions are not personalized, their efficacy might be low, due to low engagement and high drop-out rates.^21^ The use of machine learning to adapt interventions according to users’ characteristics and behaviors is still in its early stages, but shows promise.^37^ For instance, Yov-Tom et al using an adaptive learning algorithm found that adaptive feedback messages were more effective in increasing the amount and speed of PA and also reduced HbA1c in sedentary patients with type 2 diabetes.^40^ Further, Zhou et al showed short-term efficacy of using adaptive weekly step goals determined by RL in healthy patients.^38^ The current study, with a relatively large group of patients, will further increase our understanding of the potential of machine-learning-driven text-messaging interventions.

### Limitations

First, the results of this study might be specific to this population of low-income ethnic minority patients and might therefore not be generalizable to other populations. However, the inclusion of vulnerable patients in a primary care setting increases the likelihood that this intervention will be effective for other underserved populations. Further, our study procedures do not allow a double-blind design, as researchers and patients need to be made aware of the nature and frequency of messages they are receiving. Additionally, as with all digital interventions, technical issues might arise leading to unreliable step-count data and reduced ability for the algorithm to predict the most effective messages.

### Strengths

Diabetes and depression are among the top 10 causes of disability in the USA.^39^ Developing cost-effective and scalable models of care for patients with common chronic conditions has been postulated as of key importance in improving the performance of healthcare systems.^40^ If mHealth apps that target diabetes and depression through their common risk-factor physical inactivity are effective, they can have a major public health impact. Further, because the learning algorithm that we apply in this study is automated and delivers adaptive messages based on patients’ behaviors, it can potentially be applied in other patient populations with a wide range of conditions.

To conclude, the outcome of this trial will provide information on the effectiveness of a text-message-based smartphone app that uses machine learning to increase PA in low-income ethnic minority patients in primary care settings. The results will provide key information on the effectiveness of adaptive mobile applications, compared with more traditional static digital interventions. If effective, this application has the ability to decrease healthcare disparities by providing a type of personalized care to a diverse and traditionally hard to reach group of underserved patients.

## List of Publications and Products

- Aguilera, A., Arévalo Avalos, M. R., Xu, J., Chakraborty, B., Figueroa, C., Garcia, F., Rosales, K., Hernandez-Ramos, R., Karr, C., Williams, J., Ochoa-Frongia, L., Sarkar, U., Yom-Tov, E., & Lyles, C. R. (in press). Effectiveness of a Digital Health Intervention Leveraging Reinforcement Learning to Increase Daily Steps: Results from the DIAMANTE Randomized Clinical Trial. JMIR
- Nouri SS, Avila-Garcia P, Cemballi AG, Sarkar U, Aguilera A, Lyles CR. Assessing Mobile Phone Digital Literacy and Engagement in User-Centered Design in a Diverse, Safety-Net Population: Mixed Methods Study. JMIR Mhealth Uhealth. 2019;7(8), 489–497:e14250.
- Avila P, Nouri SS, Cemballi AG, Sarkar U, Aguilera A, Lyles CR. Engaging users in the design of an mHealth, text message-based intervention to increase physical activity at a safety-net healthcare system. JAMIA Open. 2019;2(4), 489–497.32025646
- Pathak-Gomez L, Aguilera A, Williams JJ, Lyles CR, Hernandez-Ramos R, Miramontes J, Cemballi A, Figueroa C. Combining User Centered Design and Crowdsourcing to Develop Messaging Content for a Physical Activity Smartphone Application Tailored to Low-income Patients. Manuscript under review at JMIR Mhealth Uhealth.
- Aguilera A, Figueroa C, Hernandez-Ramos R, Sakar U, Cemballi AG, Gomez-Pathak L, Miramontes J, Avila-Garcia P, Yom Tov E, Chakraborty B, Yan X, Xu J, Modiri A, Aggarwal J, Williams JJ, Lyles CR. An mHealth app using machine learning to increase physical activity in diabetes and depression: clinical trial protocol for the DIAMANTE Study; Manuscript under review at BMJ Open.
- Figueroa CA, Deliu N, Chakabrorty B, Modiri A, Aggarwal J, Williams JJ, Aguilera A, Lyles CR. Daily Motivational Text-messages to Promote Physical Activity in University Students: Results from A Multi-Level Micro-Randomized Trial. Manuscript Accepted in Annals of Behavioral Medicine.
- Figueroa CA, Aguilera A, Chakraborty B, Modiri A, Aggarwal J, Deliu N, Sarkar U, Jay Williams J, Lyles CR. Adaptive learning algorithms to optimize mobile applications for behavioral health: guidelines for design decisions. J Am Med Inform Assoc. 2021 Feb 28:ocab001. doi: 10.1093/jamia/ocab001. Epub ahead of print. PMID: 33657217.33657217
- Rosa Hernandez-Ramos RH, Aguilera A, Garcia FM, Miramontes J, Gomez-Pathak L, Figueroa C, Lyles CR. Conducting internet-based visits for onboarding populations with limited digital literacy onto an mHealth intervention: Development of a Patient-Centered Approach. JMIR Formative Research..

## References

1 Aguilera A, Berridge C. Qualitative feedback from a text messaging intervention for depression: benefits, drawbacks, and cultural differences. JMIR Mhealth Uhealth 2014;2:e46. 10.2196/mhealth.3660 25373390
2 Vos T, Abajobir AA, Abate KH, . Global, regional, and national incidence, prevalence, and years lived with disability for 328 diseases and injuries for 195 countries, 1990-2016: a systematic analysis for the global burden of disease study 2016. Lancet 2017;390:1211–59. doi:10.1016/S0140-6736(17)32154-2 pmid: https://www.ncbi.nlm.nih.gov/pubmed/28919117 28919117
3 Fisher EB, Chan JCN, Nan H, . Co-occurrence of diabetes and depression: conceptual considerations for an emerging global health challenge. J Affect Disord 2012;142:S56–66. doi:10.1016/S0165-0327(12)70009-5 pmid: https://www.ncbi.nlm.nih.gov/pubmed/23062858 23062858
4 Chireh B, Li M, D’Arcy C. Diabetes increases the risk of depression: a systematic review, meta-analysis and estimates of population attributable fractions based on prospective studies. Prev Med Rep 2019;14:100822. doi:10.1016/j.pmedr.2019.100822 pmid: https://www.ncbi.nlm.nih.gov/pubmed/30815337 30815337
5 Sartorius N. Depression and diabetes. Dialogues Clin Neurosci 2018;20:47–52. pmid: https://www.ncbi.nlm.nih.gov/pubmed/29946211 29946211
6 Thomas J, Jones G, Scarinci I, . A descriptive and comparative study of the prevalence of depressive and anxiety disorders in low-income adults with type 2 diabetes and other chronic illnesses. Diabetes Care 2003;26:2311–7. doi:10.2337/diacare.26.8.2311 pmid: https://www.ncbi.nlm.nih.gov/pubmed/12882854 12882854
7 Colon E, Giachello A, McIver L, . Diabetes and depression in the Hispanic/Latino community. Clin Diabetes 2013;31:43–5. doi:10.2337/diaclin.31.1.43
8 Chekroud SR, Gueorguieva R, Zheutlin AB, . Association between physical exercise and mental health in 1·2 million individuals in the USA between 2011 and 2015: a cross-sectional study. Lancet Psychiatry 2018;5:739–46. doi:10.1016/S2215-0366(18)30227-X pmid: https://www.ncbi.nlm.nih.gov/pubmed/30099000 30099000
9 Diabetes Canada Clinical Practice Guidelines Expert Committee, Sigal RJ, Armstrong MJ, . Physical activity and diabetes. Can J Diabetes 2018;42:S54–63. doi:10.1016/j.jcjd.2017.10.008 pmid: https://www.ncbi.nlm.nih.gov/pubmed/29650112 29650112
10 Cooney G, Dwan K, Greig C, . Exercise for depression Cochrane database. Syst Rev 2013;9:CD004366.
11 Mammen G, Faulkner G. Physical activity and the prevention of depression: a systematic review of prospective studies. Am J Prev Med 2013;45:649–57. doi:10.1016/j.amepre.2013.08.001 pmid: http://www.ncbi.nlm.nih.gov/pubmed/24139780 24139780
12 Avery L, Flynn D, van Wersch A, . Changing physical activity behavior in type 2 diabetes: a systematic review and meta-analysis of behavioral interventions. Diabetes Care 2012;35:2681–9. doi:10.2337/dc11-2452 pmid: http://www.ncbi.nlm.nih.gov/pubmed/23173137 23173137
13 Romeo A, Edney S, Plotnikoff R, . Can smartphone apps increase physical activity? systematic review and meta-analysis. J Med Internet Res 2019;21:e12053. doi:10.2196/12053 pmid: https://www.ncbi.nlm.nih.gov/pubmed/30888321 30888321
14 Gal R, May AM, van Overmeeren EJ, . The effect of physical activity interventions comprising wearables and smartphone applications on physical activity: a systematic review and meta-analysis. Sports Med Open 2018;4:42. doi:10.1186/s40798-018-0157-9 pmid: https://www.ncbi.nlm.nih.gov/pubmed/30178072 30178072
15 Han Y, Yan J. The effect of face-to-face interventions in promoting physical activity. Am J Nurs 2014;114:23. doi:10.1097/01.NAJ.0000445684.37306.10 pmid: https://www.ncbi.nlm.nih.gov/pubmed/24681469
16 Schrire V, Beck W. Human heart transplantation--the pre-operative assessment. S Afr Med J 1967;41:1263–5.pmid: https://www.ncbi.nlm.nih.gov/pubmed/4866698 4866698
17 Center PR. Smartphone ownership on the rise in emerging economies, 2018.
18 Vázquez MYG, Sexto CF, Rocha Álvaro, . Mobile phones and psychosocial therapies with vulnerable people: a first state of the art. J Med Syst 2016;40:157. doi:10.1007/s10916-016-0500-y pmid: https://www.ncbi.nlm.nih.gov/pubmed/27194134 27194134
19 AfHRa Q. National healthcare quality disparities report, 2016.
20 Lyles CR, Handley MA, Ackerman SL, . Innovative implementation studies conducted in US safety net health care settings: a systematic review. Am J Med Qual 2019;34:293–306. doi:10.1177/1062860618798469 pmid: https://www.ncbi.nlm.nih.gov/pubmed/30198304 30198304
21 Polgreen LA, Anthony C, Carr L, . The effect of automated text messaging and goal setting on pedometer adherence and physical activity in patients with diabetes: a randomized controlled trial. PLoS One 2018;13:e0195797. doi:10.1371/journal.pone.0195797 pmid: https://www.ncbi.nlm.nih.gov/pubmed/29718931 29718931
22 Monteiro-Guerra F, Rivera-Romero O, Fernandez-Luque L, Luque LF, . Personalization in real-time physical activity coaching using mobile applications: a scoping review. IEEE J Biomed Health Inform 2020;24:1738–1751. doi:10.1109/JBHI.2019.2947243 pmid: http://www.ncbi.nlm.nih.gov/pubmed/31751254 31751254
23 Cheung KL, Durusu D, Sui X, . How recommender systems could support and enhance computer-tailored digital health programs: a scoping review. Digit Health 2019;5:205520761882472. doi:10.1177/2055207618824727 pmid: https://www.ncbi.nlm.nih.gov/pubmed/30800414
24 Nahum-Shani I, Smith SN, Spring BJ, . Just-in-time adaptive interventions (JITAIs) in mobile health: key components and design principles for ongoing health behavior support. Ann Behav Med 2018;52:446–62. doi:10.1007/s12160-016-9830-8 pmid: https://www.ncbi.nlm.nih.gov/pubmed/27663578 27663578
25 Lyles CR, Sarkar U, Osborn CY. Getting a technology-based diabetes intervention ready for prime time: a review of usability testing studies. Curr Diab Rep 2014;14:534. doi:10.1007/s11892-014-0534-9 pmid: https://www.ncbi.nlm.nih.gov/pubmed/25173689 25173689
26 Organization WH Use of glycated haemoglobin (HbA1c) in diagnosis of diabetes mellitus: abbreviated report of a WHO consultation. Geneva: World Health Organization, 2011.
27 Bangor A, Kortum PT, Miller JT. An empirical evaluation of the system usability scale. Int J Hum Comput Interact 2008;24:574–94. 10.1080/10447310802205776
28 Yom-Tov E, Feraru G, Kozdoba M, et al.. Encouraging physical activity in patients with diabetes: intervention using a reinforcement learning system. J Med Internet Res 2017;19:e338. 10.2196/jmir.7994 29017988
29 Tewari A, Murphy SA. From ads to interventions: contextual bandits in mobile health. Mobile Health: Springer, 2017: 495–517.
30 Agrawal S, Goyal N. Analysis of thompson sampling for the multi-armed bandit problem. Conference on Learning Theory, 2012.
31 Anderson-Lewis C, Darville G, Mercado RE, et al.. mHealth technology use and implications in historically underserved and minority populations in the United States: systematic literature review. JMIR Mhealth Uhealth 2018;6:e128. 10.2196/mhealth.8383 29914860
32 Yamamoto N, Miyazaki H, Shimada M, et al.. Daily step count and all-cause mortality in a sample of Japanese elderly people: a cohort study. BMC Public Health 2018;18:540. 10.1186/s12889-018-5434-5 29685125
33 Cavero-Redondo I, Peleteiro B, Álvarez-Bueno C, et al.. The effect of physical activity interventions on glycosylated haemoglobin (HbA1c) in non-diabetic populations: a systematic review and meta-analysis. Sports Med 2018;48:1151–64. 10.1007/s40279-018-0861-0 29453742
34 Fayehun AF, Olowookere OO, Ogunbode AM, et al.. Walking prescription of 10 000 steps per day in patients with type 2 diabetes mellitus: a randomized trial in Nigerian general practice. Br J Gen Pract 2018;68:e139–45. 10.3399/bjgp18X694613 29335328
35 Manjoo P, Joseph L, Dasgupta K. Abdominal adiposity and daily step counts as determinants of glycemic control in a cohort of patients with type 2 diabetes mellitus. Nutr Diabetes 2012;2:e25. 10.1038/nutd.2011.22 23154681
36 Qiu S, Cai X, Chen X, et al.. Step counter use in type 2 diabetes: a meta-analysis of randomized controlled trials. BMC Med 2014;12:36. 10.1186/1741-7015-12-36 24571580
37 Triantafyllidis AK, Tsanas A. Applications of machine learning in real-life digital health interventions: review of the literature. J Med Internet Res 2019;21:e12286. 10.2196/12286 30950797
38 Zhou M, Fukuoka Y, Mintz Y, et al.. Evaluating machine learning–based automated personalized daily step goals delivered through a mobile phone app: randomized controlled trial. JMIR Mhealth Uhealth 2018;6:e28. 10.2196/mhealth.9117 29371177
39 US Burden of Disease Collaborators, Mokdad AH, Ballestros K, et al.. The state of US health, 1990-2016: burden of diseases, injuries, and risk factors among US states. JAMA 2018;319:1444–72. 10.1001/jama.2018.0158 29634829
40 Institute of Medicine Committee on Quality of Health Care in A Crossing the quality chasm: a new health system for the 21st century. Washington DC: National Academies Press (US), 2001