# Health-IT generated PROs to Improve Outcomes in Cirrhosis

Researchers at Virginia Commonwealth University Medical Center, along with Creative Information Technology Inc. (CITI), developed and refined two tools that aim to improve health outcomes for patients with cirrhosis. Patient Buddy is a mobile health application (app) designed to prevent readmissions by providing HIPAA-compliant and secure patient communications, monitoring medication adherence, and data analysis to keep case managers and clinicians informed of a patient’s status. EncephalApp was designed to detect and guide therapy for cognitive dysfunction among patients with cirrhosis. Patient Buddy integrates data from the electronic health record and EncephalApp to enable reporting on compliance, alert the patient when assessments are required, and notify the healthcare team when an abnormality has occurred.

The specific aims of the project are as follows:

- To evaluate in a multi-center, randomized trial the effectiveness of PROs elicited using Patient Buddy and EncephalApp with and without scheduled outpatient return visits on preventing avoidable 30-day readmissions in patients with cirrhosis and their caregivers compared to standard of care.
- To incorporate the opinion of key stakeholders (patients, caregivers, and nurse managers) toward improving the Patient Buddy App in preventing readmission in cirrhosis.

## 1 Purpose

Aim 1: To evaluate in a multi-center, randomized trial the effectiveness of PROs elicited using Patient Buddy and EncephalApp with and without scheduled outpatient return visits on preventing avoidable 30-day readmissions in patients with cirrhosis and their caregivers compared to standard of care.

Aim 2: To incorporate the opinion of key stakeholders (patients, caregivers, and nurse managers) toward improving the Patient Buddy App in preventing readmission in cirrhosis.

## 2 Scope

Patients with decompensated cirrhosis present a major healthcare burden, which is projected to increase over time^1,2^. This is primarily due to complications such as encephalopathy (HE) and volume overload/ascites that can lead to readmissions. Despite best efforts the 30-day readmission rates remain unacceptably high leading to major financial, psychosocial and clinical consequences^3–6^. Reducing readmissions will alleviate morbidity and mortality for patients and aid the current health care system towards more sustenance.

Prior studies have tried to delineate patients at high risk for readmission and attempts to enroll them in specialized clinics with mixed success^7,8^. Most studies have involved single center experiences and specialized clinics/personnel to monitor the patients and require significant time commitments from all parties and can pose a roadblock towards implementation in real world situations. Smart devices and health information technology (HIT) could offer health care providers help in tracking adherence and interacting closely with patient. This form of intervention in cirrhosis patients has been well validated and accepted by patients and their caregivers^9,10^ and in our previous publications we have shown that using the unique patient buddy app (PBA) we were able to reduce readmission. In our current multicenter study, we expanded the use of the PBA in 3 different hospital settings (1 private, 1 VA and 1 safety-net hospital) to validate this approach in a randomized clinical trial in a diverse population with the aim of reducing avoidable 30-day readmissions.

## 3 Methods (Study Design, Data Sources/Collection, Interventions, Measures, Limitations)

The trial was conducted with inpatients with cirrhosis and their caregivers, who will be followed for 30 days post-discharge. Sites participating in the trial are the Virginia Commonwealth University Medical Center, Richmond Virginia Medical Center, and Mayo Clinic in Rochester. The groups will be randomized into 2 study arms: 1) a standard of care group, 2) a group receiving Patient Buddy and EncephalApp. Additionally, the research team elicited feedback regarding the ease, safety, effectiveness, and value of these interventions. The feedback will be used to update the Patient Buddy App, which will then be available for future studies in larger populations of patients with cirrhosis. The research team hypothesizes that the patients randomized to the Patient Buddy and EncephalApp study arm will have a significantly greater reduction in hospital readmissions because of improved communication with their medical teams compared to standard of care, regardless of scheduled return outpatient visits. These were performed using a randomized controlled design with 3 sites using a randomization scheme generated at the outset. The primary endpoint was avoidable readmissions in HIT vs SOC group within 30 days of discharge to home. Secondary outcomes were all readmissions, readmissions related to various diagnoses like HE, ascites/anasarca, and infections between groups and between centers, and evaluation opinion of stakeholders regarding the performance of the App.

Eligible participants were cirrhosis patients >21 years of age who were hospitalized for non-elective reasons meeting these inclusion criteria (a) cirrhosis diagnosed either upon radiological, biopsy features or as evidenced by decompensation of cirrhosis (with ascites, variceal bleeding, or hepatic encephalopathy) (b) having an adult care giver (CG) living with the patient in the same house (c) able to complete the PBA training and evaluation (d) discharged home from the hospital. These were approached for enrollment. Those excluded were (a) patients admitted with alcohol-related hepatitis (b) without available CGs at home (c) unable to perform training or give consent (d) patients with poor English proficiency (e) discharged to hospice or those on hemodialysis (f) without stable housing or stable internet connection at home (g) those not able to consent or understand the study (h) and pregnant patients. Absence of phones was not a barrier to recruitment since phones were provided to the patients and CGs as part of the trial.

Patients, caregivers, and providers were engaged in questionnaires about the study and Apps during and after the study. Reason(s) for participation or not were also inquired.

The primary endpoint was defined by board consisting of physicians from all 3 sites who were not involved in the study and who were blinded to the randomization scheme. They were provided de-identified index admission and discharge and readmission details to make their decision and voted. The study team was informed of their decision.

## 4 Results

### Results of 2 studies that have been published

#### Paper #1

Acharya C, Sehrawat TS, McGuire DB, Shaw J, Fagan A, McGeorge S, Olofson A, White MB, Gavis E, Kamath PS, Bergstrom L, Bajaj JS. Perspectives of inpatients with cirrhosis and caregivers on using health information technology: Cross-sectional multicenter study. J Med Internet Res. 2021 Apr 9;23(4):e24639. doi: 10.2196/24639. PMID: 33744844; PMCID: PMC8065567.33744844

Abstract and results:

Objective: The aim of this study was to determine perspectives regarding adoption versus refusal of health IT interventions among patient-caregiver dyads.

Methods: Inpatients with cirrhosis and their caregivers were approached to participate in a randomized health IT intervention trial requiring daily contact with research teams via the Patient Buddy app. This app focuses on ascites, medications, and hepatic encephalopathy over 30 days. Regression analyses for characteristics associated with acceptance were performed. For those who declined, a semistructured interview was performed with themes focused on caregivers, protocol, transport/logistics, technology demands, and privacy.

Results: A total of 349 patient-caregiver dyads were approached (191 from Virginia Commonwealth University, 56 from Richmond Veterans Affairs Medical Center, and 102 from Mayo Clinic), 87 of which (25%) agreed to participate. On regression, dyads agreeing included a male patient (odds ratio [OR] 2.08, P=.01), gastrointestinal bleeding (OR 2.3, P=.006), or hepatic encephalopathy admission (OR 2.0, P=.01), whereas opioid use (OR 0.46, P=.03) and alcohol-related etiology (OR 0.54, P=.02) were associated with refusal. Race, study site, and other admission reasons did not contribute to refusing participation. Among the 262 dyads who declined randomization, caregiver reluctance (43%), perceived burden (31%), technology-related issues (14%), transportation/logistics (10%), and others (4%), but not privacy, were highlighted as major concerns.

Conclusions: Patients with cirrhosis admitted with hepatic encephalopathy and gastrointestinal bleeding without opioid use or alcohol-related etiologies were more likely to participate in a health IT intervention focused on preventing readmissions. Caregiver and study burden but not privacy were major reasons to decline participation. Reducing perceived patient-caregiver burden and improving communication may improve participation.

Important implications “Reasons for patients with cirrhosis and their caregivers declining to participate in a trial using an intensive app that requires 30 days of feedback regardless of demographics and clinical settings were mainly related to caregiver and study demands, but importantly not to privacy concerns. Those admitted with hepatic encephalopathy and gastrointestinal bleeding issues were more likely to agree to participate, whereas those with alcohol etiology and opioid use were less likely to participate in the health IT study. Further research should address the careful balance of patient and caregiver burdens with clinicians’ needs for accurate and timely information that enables good disease management.”

#### Paper #2

Shaw J, Acharya C, Albhaisi S, Fagan A, McGeorge S, White MB, Lachar J, Olson J, Olofson A, Bergstrom L, Kamath PS, Bajaj JS. Subjective and objective burden on providers from a multicenter app-based study of patients with cirrhosis and caregivers. Hepatol Commun. 2023 Jan 27;7(2):e0030. doi: 10.1097/HC9.0000000000000030. PMID: 36706194; PMCID: PMC9988316.36706194

Abstract and results:

Background: App-based technologies could enhance patient and caregiver communication and provide alerts that potentially reducing readmissions. However, the burden of App alerts needs to be optimized to reduce provider burnout.

Aim: The purpose of this study was to determine subjective and objective burden of using the Patient Buddy App, a health information technology (HIT) on providers in a randomized multicenter trial, who completed a semi-quantitative Likert scale survey regarding training procedures, data and privacy concerns, follow-up details, and technical support. This randomized multicenter trial recruits cirrhosis inpatients and their caregivers, and randomizes them into standard-of-care, for 30 days after discharge. The alerts are monitored by providers through a central iPad. The reason(s) and number of alerts were recorded as the objective burden. A total of 1442 messages were sent as alerts from the 103 dyads (patient + caregiver) (n=206) randomized to HIT arms. The most common messages related to Hepatic Encephalopathy (HE) (high or low bowel movement=50% or orientation tests=37%). Twelve providers completed the surveys reflecting the following themes—92% and 100%, felt adequately trained and confident about educating the patients and caregivers before roll out of App and had no concerns related to data and privacy; 70%, felt that appropriate time was spent on pursuing reason for data not being logged; 60% each, had issues with availability of adequate technical support and connectivity.

Conclusion: The Patient Buddy App randomized multicenter trial till date shows an overall favorable rating regarding training procedures/education, privacy concerns, and ease of message follow-up, from providers. However, it is important to gauge and address subjective and objective burdens of monitoring human resources in current and future HIT studies to avoid burnout and to ensure successful study completion.

Important implications: “Using semi-quantitative questionnaires, providers engaged in enrolling, monitoring, and responding to patients with cirrhosis and their caregivers over 30 days after discharge have an overall favorable rating regarding training procedures, education, privacy concerns, and ease of following up on the message details, from providers. However, clearly there is a scope for improvement in availability of technical support and connectivity aspects for providers, which can easily result in improvements by the technology partners. Given the large burden of alerts and technical demands generated, App-based studies that track several symptoms such as confusion, weight gain, and infections in patients with cirrhosis need adequate training, back-up plans, and staff numbers to prevent burnout in providers monitoring these high-risk subjects. Future studies based on Apps and patient-facing interfaces should consider not only patient and caregiver, but also provider burden to ensure optimal supervision and monitoring.”

## 5 List of Publications and Products

### Published papers

Perspectives of inpatients with cirrhosis and caregivers on using health information technology: Cross-sectional multicenter study.

Citation

Acharya C, Sehrawat TS, McGuire DB, Shaw J, Fagan A, McGeorge S, Olofson A, White MB, Gavis E, Kamath PS, Bergstrom L, Bajaj JS. Perspectives of inpatients with cirrhosis and caregivers on using health information technology: Cross-sectional multicenter study. J Med Internet Res. 2021 Apr 9;23(4):e24639. doi: 10.2196/24639. PMID: 33744844; PMCID: PMC8065567.33744844

Principal Investigator

Bajaj, Jasmohan S.

Project Name

Health IT-Generated PROs to Improve Outcomes in Cirrhosis

Subjective and objective burden on providers from a multicenter app-based study of patients with cirrhosis and caregivers.

Citation

Shaw J, Acharya C, Albhaisi S, Fagan A, McGeorge S, White MB, Lachar J, Olson J, Olofson A, Bergstrom L, Kamath PS, Bajaj JS. Subjective and objective burden on providers from a multicenter app-based study of patients with cirrhosis and caregivers. Hepatol Commun. 2023 Jan 27;7(2):e0030. doi: 10.1097/HC9.0000000000000030. PMID: 36706194; PMCID: PMC9988316.36706194

Principal Investigator

Bajaj, Jasmohan S.

Project Name

Health IT-Generated PROs to Improve Outcomes in Cirrhosis

### Accepted abstracts that are not published currently

A Health IT Intervention with Caregiver Engagement Significantly Reduces Avoidable Readmissions in A Multi-Center Randomized Clinical Trial of >450 participants: The HEROIC Trial.

Accepted for an oral presentation at the 2024 Liver Meeting to be held in November 2024 in San Diego.

Citation

Shaw J, Acharya C, Fagan A, Olofson A, McGeorge S, Montano M, Kamath PS, Bajaj JS

Investigator

Bajaj, Jasmohan S.

Project Name

Health IT-Generated PROs to Improve Outcomes in Cirrhosis

## References

1 Desai AP, Mohan P, Nokes B, . Increasing Economic Burden in Hospitalized Patients With Cirrhosis: Analysis of a National Database. Clin Transl Gastroenterol 2019; 10(7): e00062.31343469
2 Moon AM, Singal AG, Tapper EB. Contemporary Epidemiology of Chronic Liver Disease and Cirrhosis. Clin Gastroenterol Hepatol 2020; 18(12): 2650–66.31401364
3 Orman ES, Desai AP, Ghabril MS, . Thirty-Day Readmissions Are Largely Not Preventable in Patients With Cirrhosis. Am J Gastroenterol 2024; 119(2): 287–96.37543729
4 Bajaj JS, Reddy KR, Tandon P, . The 3-month readmission rate remains unacceptably high in a large North American cohort of patients with cirrhosis. Hepatology 2016; 64(1): 200–8.26690389
5 Garg SK, Goyal H, Obaitan I, . Incidence and predictors of 30-day hospital readmissions for liver cirrhosis: insights from the United States National Readmissions Database. Ann Transl Med 2021; 9(13): 1052.
6 Chirapongsathorn S, Poovorawan K, Soonthornworasiri N, Pan-Ngum W, Phaosawasdi K, Treeprasertsuk S. Thirty-Day Readmission and Cost Analysis in Patients With Cirrhosis: A Nationwide Population-Based Data. Hepatol Commun 2020; 4(3): 453–60.32140661
7 Pusateri A, Litzenberg K, Griffiths C, . Randomized intervention and outpatient follow-up lowers 30-d readmissions for patients with hepatic encephalopathy, decompensated cirrhosis. World J Hepatol 2023; 15(6): 826–40.37397939
8 Morales BP, Planas R, Bartoli R, . HEPACONTROL. A program that reduces early readmissions, mortality at 60 days, and healthcare costs in decompensated cirrhosis. Dig Liver Dis 2018; 50(1): 76–83.28870446
9 Ganapathy D, Acharya C, Lachar J, . The patient buddy app can potentially prevent hepatic encephalopathy-related readmissions. Liver Int 2017; 37(12): 1843–51.28618192
10 Shaw J, Acharya C, Albhaisi S, . Subjective and objective burden on providers from a multicenter app-based study of patients with cirrhosis and caregivers. Hepatol Commun 2023; 7(2): e0030.36706194