# Incorporating PRO data into RA Clinical Encounters using Health-IT (PACT)

## PURPOSE

The objectives of this study were to build, implement, and test an application to display PRO scores for patients with RA during a clinical visit. The application was designed to visually represent the trajectory of an individual with RA, include clinical and patient-reported information, and frame this course within the context of accepted clinical targets. In Aim 1, we engaged a professional design team to work with patients and clinicians to develop a prototype front-end user-interface that can be used to communicate PRO data to patients and clinicians during routine clinical care. In Aim 2, we worked with our clinical informatics teams to build the application and launch it at the UCSF Health rheumatology clinic. In Aim 3, we performed a pragmatic trial to test whether the availability and use of the PRO application affected patient-centered outcomes, such as medication adherence and shared decision making, and additional RA outcomes.

## SCOPE

With an ever-growing body of electronic health record (EHR) data, including patient-reported outcomes (PROs), one important role for health information technology (IT) tools is to help summarize this data for incorporation into real-time clinical decision making. Graphical displays of structured data (such as blood pressure, BMI, hemoglobin A1C, and other laboratory test results) are commonly available in many EHRs or patient portals, and can be used by clinicians or patients.^1,2^ However, there has been less progress in developing tools to track chronic disease outcomes. For example, even when documented as structured data in the EHR, patient-reported outcomes are not easily tracked over time for seamless interpretation by clinicians or patients during a clinical visit.^3,4^

Optimization of the EHR to facilitate chronic disease care has been slow. Approaches such as working with large EHR vendors to customize foundation software for chronic disease care, or constructing local customizations of existing EHR software, have yielded little progress. Other approaches such as developing parallel systems entirely outside the EHR have important disadvantages such as requiring clinicians to work with multiple interfaces. EHR sidecar applications offer a potential solution to some of these challenges because these applications offer more design flexibility and can fully integrate with the EHR, avoiding the complexities of requiring interactions with multiple applications.

Informed by digital innovation best practices, we embarked on the design, development and implementation, and evaluation of an EHR sidecar application for a common chronic condition, rheumatoid arthritis (RA). RA is a chronic inflammatory disease in which individuals develop joint pain, stiffness, and swelling. It is a pertinent case study for development of a sidecar application because the condition has several key disease outcomes, including disease activity, functional status, and pain, which are captured routinely as structured fields in the EHR. Although the effective use of PRO data in RA has been documented to improve health outcomes, prior studies have shown that communication around these outcomes, even when documented in the EHR, is limited in real-world practice.^5,6,7,8^

## METHODS

Our overall approach was based on an adaptation of a well-known digital innovation process to describe the development, integration, and maintenance of our EHR sidecar application (Figure 1). The roadmap included human-centered design, Agile product development, and lean/clinic deployment, and were divided into a “problem solving phase” and “execution and solution-building phase.” Finally, we embarked on a pragmatic clinical trial to test whether clinician access to the dashboard had measurable effects on patient outcomes; we also and completed qualitative evaluations of the dashboard with patients and clinicians.

Figure 1 Roadmap for the development and deployment of an EHR sidecar application to track patient outcomes in rheumatoid arthritis. Adapted from Gartner

Screenshot of roadmap for the development and deployment of an EHR sidecar application to track patient outcomes in rheumatoid arthritis as described in the paragraph above.

### Aim 1

Guided by principles of human-centered design, we tested various dashboard prototypes during a series of six focus groups (FGs) with patients and three FGs with clinicians to arrive at an optimal dashboard design. Patients were eligible for the study if they had a diagnosis of RA, were ≥18 years old, were primarily English- or Spanish-speaking and received care in rheumatology clinics at either a university hospital or in a county hospital based in California. Using purposeful sampling, we contacted patients with previously documented adequate or limited health literacy via phone to participate in the FGs. Modest compensation was provided for patient participation.

For the clinician FGs, eligible clinicians included fellow trainees, faculty rheumatologists and other members of the health-care team (nurse practitioners or medical assistants) who worked at these sites. FGs were conducted in person, facilitated by native speakers in each language who had qualitative research and facilitation expertise and lasted 60-90 minutes. We solicited feedback and made iterative changes to mock-ups of an RA dashboard that visualized PROs using a human-centered design process. All FGs were audio recorded and transcribed verbatim and, for the Spanish focus groups, translated. We used iterative inductive and deductive thematic analysis method to identify and characterize themes from the focus groups and used these insights to refine the dashboard.

The specific actions table in the design of the RA PRO dashboard are explained in Table 1.

Table 1 Specific actions taken in the design of the RA PRO dashboard

Design Thinking Phase | Actions Taken
Human-centered design process | We worked with patients and clinicians, researchers, and the technology team on a human centered design (HCD) process.
Proposed clinical workflow | Based on our human-centered design work, we developed a proposed workflow incorporating the RA PRO dashboard into a clinical visit
Minimum viable product definition | Key feature selection and prioritization was derived from the human centered design process. We used the Technology Acceptance Model (TAM) as guiding framework for feature selection.

### Aim 2

With the support of our technical team, we undertook the development and implementation of the RA PRO dashboard at the UCSF Health clinic, which uses Epic as its EHR. The specific actions taken in the development and deployment of the RA PRO dashboard are shown in Table 2.

Table 2 Specific actions taken in the development and deployment of the RA PRO dashboard

Phase | Actions taken
Agile Development
EHR integration approach | We selected EHR integration via a side-car application based on ability to customize the interface and low institutional license fees.
Risk assessment and approvals | Our proposed architecture needed to be shared with the Digital Diagnostics and Therapeutics Committee before the build could begin. After the application was built and tested, we returned to get a final approval prior to deployment.
Scrum | We used storyboards to identify and prioritize key features, followed by 2-week sprints.
Launch to test environment and user testing | User testing in the sandbox environment occurred by the user interface designer in the clinic with 4 providers (including 2 attendings and 2 fellow physicians).
Launch to production and user testing | After testing and final risk assessments, the application was launched into the production environment.
Clinic deployment / Lean
User orientation and education | Study staff developed training and development of educational materials to encourage clinicians, patients, and other clinic personnel to highlight the features of the dashboard.
Continuing education and support | We developed training guides and educational resources for patients, clinic staff, and physicians in order to improve their understanding and promote use of PROs during routine clinical care.
Monitoring actual use | We distributed reports to clinicians and clinic leadership to track the quality of the data entering the dashboard (i.e., the collection of PROs and RA outcomes) and monitored engagement with the dashboard using user audit logs.
Application maintenance | We established a comprehensive set of strategies to effectively manage and maintain the application over time including content updates, software and security updates, and major changes to clinical workflows.

### Aim 3

#### Stepped wedge trial

In Aim 3, we implemented a stepped-wedge pragmatic cluster-randomized trial at the UCSF Health clinic between February 2020, and August 2023. Clinicians in the UCSF Health rheumatology clinic (attending rheumatologists, rheumatology fellows, and a rheumatology nurse practitioner), were randomized to gain access to the RA PRO dashboard (intervention) at 4 different time points during the study period (Figure 2). We assessed patient outcomes during a baseline period (before launch of the RA PRO dashboard) and then with visits that occurred over course of the study period. Eligible subjects were adults, aged 18 years or older, at least 1 RA outpatient visit at the UCSF Health rheumatology clinic and at least 2 ICD codes for RA, ≥ 30 days apart and at least one of CDAI, PROMIS, or pain score documented. Patients were excluded if they were unable to read, speak, or understand English or if they could not provide informed consent. Patients were invited to participate during a clinical visit and verbal consent was obtained. Questionnaires were typically completed in-person by patients immediately following a clinician visit or by phone within 7 days following the visit. During the baseline period (which coincided with the COVID-19 pandemic), patients could also be called via telephone to complete questionnaires asynchronously with their clinic visits.

Figure 2 Stepped Wedge Randomized Control Trial Schematic

Stepped wedge Randomized Control Trial Schematic of the 4 different time cluster within the baseline period vs. intervention, as described in the paragraph above. • Cluster 1 (4 providers): Base period from February 26,2 021 to August 10, 2021. Intervention from August 11, 2021 to August 21, 2023. • Cluster 2 (5 providers): Base period from February 26, 2021 to May 1, 2022. Intervention from May 2, 2022 to August 21, 2023. • Cluster 3 (6 providers): Base period from February 26, 2021 to August 10,2021. Intervention from August 11,2021 to August 21, 2023. • Cluster 4 (8 providers): Base period from February 26, 2021 to September 26, 2021. Intervention from September 27,2022 to August 21, 2023.

Three data sources were used in this study:

1. Patient questionnaire responses: derived from questionnaires completed by the patients and clinical outcomes collected during routine care:
  a. The SURE Test: 4-item scale that measures decisional conflict in patients using a binary scale (0 = “no”; 1 = “yes”). A higher score indicates greater decisional clarity.
  b. The PROMIS Short Form v1.0 – Self-Efficacy for Managing Symptoms 4a (PROMIS-SE): a 4-item scale that measures self-efficacy in symptom management using a 5-point Likert-type scale (1 = “not at all confident”; 5 = “very confident”) for a raw score range of 4 to 20, translated into T-scores with a mean of 50, and a standard deviation of 10. A higher T-score indicates greater self-efficacy.
  c. The Beliefs about Medicines Questionnaire – Specific (BMQ-Specific): two 5-item subscales that assess patients’ beliefs about their need for medication to maintain health (Specific-Necessity) and their concerns about its potential negative effects (Specific-Concerns) using a Likert-type scale (1 = “strongly agree”; 5 = “strongly disagree”) for a simple sum of 5 to 25 points for each subscale. We use the survey to calculate the Necessity-Concerns differential (Specific-Necessity minus Specific-Concerns) to assess patients’ need for medication in comparison to their concerns. Scores range from -20 to +20, where a positive score indicates that necessity beliefs outweigh concerns.
  d. Medication adherence: a single item (“How many times do you think you may have missed taking your pills in the last week?”)
2. Patient EHR data for clinical outcomes and information on covariates: CDAI and PROMIS-PF10), which are routinely collected during clinical care and documented on the same day as the visit. For purposes of the trial, we examined CDAI score and PROMIS-PF t-score.
3. Clinician dashboard user log data, which was monitored via the dashboard itself via Google Analytics. Dashboard utilization was defined as any action of the dashboard, including page scrolling, printing, refreshing, showing/hiding any elements or lab results, and scrolling the timeline backwards or forwards.

The primary analysis was an intention-to-treat analysis which defined the intervention based on the dates on which clinicians gained access to the RA PRO dashboard. Mixed-effects regression models compared the average score of each instrument during the intervention period to the control period. The models included fixed effects for randomized intervention groups (yes/no) and time periods (included as an ordinal categorical variable with 4 levels) as well as random effects (random intercept and random slope) to account for within-cluster correlation in repeated patient outcomes. Regression results are summarized as estimated coefficients with 95% confidence intervals. A p-value < 0.05 was considered statistically significant. Because analyses of secondary outcomes were not adjusted for multiple testing, these findings should be considered exploratory. Analyses were performed using Stata 18.

#### Qualitative evaluation

[underlined: Clinicians FGs:] We conducted FG discussions with clinicians who had access to the RA PRO dashboard. At cluster two (in April 2022) we contacted by email all clinicians with access to the dashboard to participate in the first focus group (FG) (n=9). At cluster three (in August 2022) we contacted all clinicians with access to the dashboard (n=15) to participate in the second FG. At cluster four (in October 2022) we contacted all clinicians with access to the dashboard (n=23) to participate in the third FG. FGs explored clinician perceptions towards the usability, acceptability, and usefulness of the dashboard. The FGs, conducted virtually via Zoom between April and October 2022, lasted between 30 to 40 minutes, were audio recorded, and then transcribed verbatim. FG data were analyzed thematically using deductive and inductive techniques; generated themes were categorized into the domains of the Technology Acceptance Model (TAM).

[underlined: Patient interviews:] Using purposive sampling and ensuring that a range of usability perspectives were included, we invited 143 RA patients to participate in semi-structured interviews. Interviews were conducted virtually via Zoom by a qualitative researcher between November 2022 and April 2023 and were guided by a semi-structured interview guide that assessed patients’ perceptions towards RA PRO measures and explored their experience with the RA PRO dashboard shared by their rheumatologist during their clinical visit. Interviews lasted between 20 to 45 minutes and were audio-recorded, transcribed verbatim and analyzed thematically using deductive and inductive techniques. Emerging themes and subthemes were organized into the domains of the ecological model.

## RESULTS

### Aim 1 RA PRO Dashboard Prototype and Workflow design

Through a human centered design process, we iterated a prototype of the RA PRO Dashboard (Figure 3). Sections included ‘My RA symptoms’, representing the CDAI disease activity score, ‘How well can I function’ showing PROMIS physical function scores, and ‘My pain’. Medication and laboratory information were also displayed. We also developed a proposed workflow incorporating the RA PRO dashboard into a clinical visit (Figure 4).

Figure 3 Prototype of RA PRO Dashboard

Prototype of RA PRO Dashboard, as described in the paragraph above.

Figure 4 Workflow incorporating the RA PRO dashboard into a clinical visit

Workflow incorporating the RA PRO dashboard into a clinical visit, as described in the paragraph above. Including the following steps: 1. Pre-visit data is auto-loaded from HER into Ann’s RA dashboard. 2. During An’s visit, Dr. Gomez updates HER with data from her exam, such as swollen and tender joints. This data updates her dashboard. 3. Dr. Gomez launches Ann’s dashboard from the RA Navigator in Epic. 4. Dr. Gomez and Ann look at all of her data together and discuss progress, medication, treatment, lifestyle, and goals. 5. Ann takes a printout of these options with her, which she can also access later through MyChart. 6. Later she references the printout when discussing her medication options with her sister.

### Aim 2

After the human design phase, the build for the RA PRO dashboard sidecar application required extensive regulatory approvals, software development, user testing, integration with Epic-based workflows, and maintenance. Key requirements were prioritized based on the anticipated effects on usefulness and ease of use. Final screenshot of the dashboard is shown in Figure 5. Implementation science strategies were used to improve use of the dashboard in clinic and included education for patients, staff, and clinicians; reports of actual use of the dashboard and data quality; and regular meetings between the research team and clinicians to discuss and address barriers to use. Our approach focused on supporting positive user attitudes and behavioral intentions to use the dashboard according to the CFIR framework (Table 3). Collection of user log data was an important part of our Lean process, since meaningful changes in number of sessions or specific actions on the dashboard heralded maintenance issues with the dashboard: these included content updates such as medication additions, software system updates, and major changes to clinical workflows (Table 4).

Figure 5 Final screenshot of RA PRO dashboard

Final Screenshot of RA PRO dashboard, as described in paragraph above.

Table 3 Implementation science concepts as applied to the clinic deployment of the RA PRO dashboard

Strategy | CFIR construct | Description | Explanation
Clinician orientation sessions | Process of Implementation | The research team provided individual, in-person orientation sessions lasting between 10 to 15 minutes at the time each clinician was provisioned to have access to the dashboard. | Orientation sessions included a general description of the objectives of the dashboard and its features.
Bimonthly conferences to discuss deployment with clinicians | Inner Setting | Brief bimonthly conferences were organized to elicit feedback about the dashboard from clinicians. | Over the first year that the dashboard was deployed we held 4 conferences for all clinicians to attend as part of regularly scheduled faculty meetings. Discussion included successes and challenges in using the dashboard and allowed clinical champions to share best practices for using the dashboard.
Clinician educational resources | Characteristics of clinicians | Teaching sessions, educational handouts, and scripts on how to collect and discuss PROs were shared with clinicians. | Training on RA outcomes and PROs were incorporated into regular teaching sessions for trainees along with information on how to score PROs with all clinicians. We also provided clinicians scripts for how to discuss PROs with patients.
Training for nurses and medical assistants | Inner setting | We developed a guide and trained nurses and medical assistants (MAs) on collecting RA PROs. The training focused on collecting the patient global assessment component of the CDAI, PROMIS-PF, and the pain scores, and entering the data into the EHR. | This training provided information about RA PROs and the importance of collecting these measures. The goal was to increase clinical staff knowledge on the importance of collecting PROs, with the hope that this would motivate their collection of PROs – with more data available, this could enhance the use of the dashboard by clinicians.
Resources for patients | Inner setting | We developed an information sheet for patients explaining the types, meaning, importance, and use of the different PROs collected before and during visits at the rheumatology clinic. | The information sheet increased patient awareness and understanding of the types and meaning of the RA outcomes collected before and during their RA visit and helped motivate them to complete the PRO surveys and measures offered to them in the waiting room.
Audit log and data quality reports share with clinic leaders | Outer setting | We generated reports using EHR data (the same data used for display on the dashboard) to share with clinicians and clinic staff. Second, we tracked actual use of the dashboard over time using audit-log data from Google Analytics. | These reports were provided to clinic leadership and individual clinicians on a weekly and monthly basis.

Table 4 Maintenance issues related to building an EHR-integrated sidecar application

Maintenance category | Example issue | Potential solutions
Content updates | New medications/new versions of existing medications) are continually becoming available. | 1. Set regular update timelines (monthly, quarterly); 2. Design application to be able to accommodate changes or additions to variable names
Software updates | Because there were so many systems involved in the application, software or security updates to component systems were continual, including updates to the EHR, sandbox environments, Salesforce, and Google Analytics. | 1. Plan for continued engagement with technology team to respond to software updates; 2. Look ahead and know when software updates will occur to anticipate potential downstream consequences; 3. Monitor data streams (e.g. user audit logs) and create alerts for reduced or missing data for early identification of problems
Major changes to clinical workflows | The explosion of telehealth visits during the COVID-19 pandemic resulted in a sharp decrease in the collection of RA outcomes, since assessment of disease activity (tender and swollen joints) requires a physician exam. | Routine data quality assessments Stratification of quality assessments based on visit type

### Aim 3

Overall, 23 clinicians were included in the analysis and 554 patients completed 1083 patient questionnaires. Among 1083 questionnaires, 272 (25.1%) were in the intervention group. Characteristics of the patients are summarized in Table 5. Results are summarized Table 6; statistical models are shown in Table 7. Briefly, patients were older, mostly female, White non-Hispanic, and carried Medicare insurance. Most had moderate-high disease activity based on CDAI and were receiving csDMARDs, bDMARDs, and low doses of glucocorticoids. We did not observe statistically significant differences in the control vs. intervention groups on SURE, PROMIS 4a, BMQ, or medication adherence questionnaires. We did not see differences in CDAI. Small improvements in PROMIS-PF were observed, although the clinical significance of this is not clear.

Table 5 Patient survey-level demographic and clinical characteristics by study group

Characteristics | Control | Intervention
Number of patient surveys | 811 | 272
Number of patients | 554 | 186
Age, y, mean (SD) | 60.6 (14.9) | 63.8 (13.3)
Gender
Female | 674 (83.1) | 243 (89.3)
Male | 137 (16.9) | 29 (10.7)
Race and ethnicity
White | 469 (57.8) | 150 (55.1)
Asian | 125 (15.4) | 41 (15.1)
Hispanic | 92 (11.3) | 34 (12.5)
Black/African American | 63 (7.8) | 28 (10.3)
Mixed/other | 48 (5.9) | 14 (5.1)
unknown | 14 (1.7) | 5 (1.8)
Insurance
Medicare | 411 (50.7) | 161 (59.2)
Private/Commercial | 282 (34.8) | 84 (30.9)
Medicaid | 101 (12.5) | 24 (8.8)
Other | 17 (2.1) | 3 (1.1)
Baseline clinical characteristics (closest record from an “18 months prior and 2 months after” window to the patient’s first survey)
CDAI, n | 427 | 202
moderate or high score (n (%)) | 239 (56.0) | 127 (62.9)
low or remission (n (%)) | 188 (44.0) | 75 (37.1)
PROMIS 10 PF, n | 646 | 239
median (interquartile range) | 41 (36.3 - 48) | 40.2 (34.2 - 47.7)
Pain, n | 609 | 218
median (interquartile range) | 39 (13 - 65) | 44.5 (13 - 68)
RA Medications (yes/no, n (%))
tDMARDs | 50 (6.2) | 13 (4.8)
cDMARDs | 644 (79.4) | 202 (74.3)
bDMARDs | 454 (56.0) | 165 (60.7)
Glucocorticoids | 451 (55.6) | 161 (59.2)

Data are presented as No. (%) unless otherwise specified.

Table 6 Primary and secondary outcomes by study group

| Control | Intervention
Number of patient surveys | 811 | 272
Number of patients | 554 | 186
Primary outcome: patient questionnaire outcomes
4-item SURE screening^a^, n | 682 | 265
median (IQR) | 4 (3 – 4) | 4 (3 – 4)
PROMIS 4a – Symptom Management^b^, n | 777 | 260
median (IQR) | 49.5 (46.9 – 52.2) | 49.5 (44.4 – 50.9)
Number of days missed medications in the past week, n | 762 | 247
median (IQR) | 0 (0 – 0) | 0 (0 – 0)
Beliefs about Medicine Questionnaire (BMQ)^c^
specific-necessity, n | 652 | 256
median (IQR) | 23 (19 – 25) | 23.5 (21 – 25)
specific-concern, n | 646 | 253
median (IQR) | 13 (10 -17) | 13 (9 -16)
BMQ Necessity-concerns differential^d^, n | 634 | 250
median (IQR) | 8 (4 - 13) | 9.5 (5 - 14)
Secondary outcome: RA outcomes
CDAI, n | 477 | 472
median (IQR) | 9.5 (4.1 – 19.0) | 9.9 (4.3 - 16.7)
PROMIS PF10, n | 762 | 487
median (IQR) | 41.0 (36.3 - 47.7) | 39.4 (34.3 - 46)

a The 4-item SURE (Sure of myself; Understand information; Risk-benefit ratio; Encouragement) screening tests for decisional conflict in patients. A response of yes scores 1 and a response of no scores 0; a score of < 4 is a positive result for decisional conflict.

b PROMIS (Patient-Reported Outcomes Measurement) 4a – Symptom Management is a 4-item questionnaire that is rated on a scale from 1 to 5, with 1 being “not at all confident” and 5 being “very confident” in the patient’s ability to manage the symptoms of their disease. Raw scores range from 5 to 20 and can be translated into t-scores, with a mean of 50 and a standard deviation of 10, for comparison with the U.S. general population mean. A higher t-score represents more confidence in ability to manage disease symptoms.

c The BMQ answers are scored from 1 (strongly disagree) to 5 (strongly agree). Specific-necessity and specific-concerns scales have 5 items, and scores range from 5 to 25. Higher specific-necessity scores represent stronger perceptions of personal need for the medication to maintain health now and in the future. Higher specific-concerns scores represent stronger concerns about the potential negative effects of the medication. Points of each scale are summed to give a scale score. Higher scores indicate stronger beliefs in the concepts of the scale

d The BMQ Necessity-concerns differential is calculated by subtracting the concern score from the necessity score. A positive score indicates the individuals have stronger beliefs in the necessity of the medication relative to the concern.

Table 7 Estimated coefficients of intervention group for primary and outcomes

| Control group | Intention to treat analysis
| Control group | Coef. (95%CI) | p
Primary outcomes
4-item SURE | reference | 0.01 (-0.13 - 0.15) | 0.90
PROMIS4a | reference | -0.32 (-1.26 - 0.63) | 0.51
number of days missed medication | reference | -0.04 (-0.14 - 0.07) | 0.51
BMQ difference | reference | 0.43 (-0.29 - 1.15) | 0.24
Secondary Outcomes
CDAI | reference | -0.20 (-1.63 - 1.22) | 0.78
PROMIS PF 10 | reference | -1.58 (-3.11 - 0.04) | 0.04

All estimates were from mixed-effect models including fixed effects for the randomized intervention group (yes/no) and time periods (included as an ordinal categorical variable with 4 levels) as well as a random intercept.

Dashboard engagement: Over the course of the study period, there were 14 out of 23 (60.9%) clinicians who engaged actively with the dashboard by scrolling the page, showing different elements, and/or reviewing historical data with their patients. There was wide variation in the dashboard engagement across all clinicians (range 0 – 36.8%).

Our qualitative analysis had several important findings.

[underlined: Clinician focus groups:] Overall, clinicians were enthusiastic about the dashboard and expressed the usefulness of visualizing RA outcome trajectories in a graphical format for motivating patients, enhancing patient understanding of their RA outcomes, and improving communication about medications. Major themes that emerged from the FG analysis as barriers to using the dashboard included inconsistent collection of RA outcomes leading to sparse data in the dashboard and concerns about explaining RA outcomes, especially to patients with fibromyalgia. Other challenges included time constraints and technical difficulties refreshing the dashboard to display real-time data. Methods for integrating the dashboard into the visit varied: some clinicians used the dashboard at the beginning of the visit as they documented RA outcomes; others used it at the end to justify changes to therapy; and a few shared it only with stable patients.

[underlined: Patient interviews:] We conducted 29 interviews. Emerging themes and subthemes were organized into four domains of the Ecological Model of Health. Patients considered routine assessment and use of RA PROs could be useful for at the patient, clinician, interpersonal, and clinic levels. In addition to increasing knowledge and understanding of their disease, PROs encouraged them to reflect on their health and supported interpersonal communication about RA, medications, and other disease-related topics with their clinicians. Second, the use of the RA PRO dashboard was appreciated by most patients who requested seeing the dashboard at every RA visit. It was perceived as an important visual tool that enhanced clinical encounters by improving patients’ understanding about the use and benefits of collecting PRO measures, enhancing their involvement in RA care, and increasing trust in clinicians and the clinic. Common limitations included concerns about the suitability of PRO measures for all patients and inconsistent collection and explanation of these measures.

## DISCUSSION

In this project we successfully designed, developed, and tested an EHR sidecar application for RA, a common chronic condition in ambulatory care. Grounded in human-centered design principles, the development process was led by an internal technology team familiar with established software development practices at our institution. To ensure effective adoption of the dashboard within our clinical setting, we invested significant efforts into clinical implementation, developing orientation and educational materials tailored for clinicians, medical staff, and patients. We also employed systems for monitoring data quality and tracking actual usage of the dashboard.

We found the technology acceptance model (TAM) an especially useful framework for prioritizing tasks to maximize usability and ease of use for clinicians, clinic staff, and patients. As part of our approach, we prioritized certain features to improve the dashboard’s functionality. These included personalized axes for graphical ranges, a toggle button to show or hide additional PROs and detailed lab data per physician preferences, and the inclusion of target ranges for disease activity and physical function represented by a “green zone” on each graph. However, during the development process, we had to make several challenging decisions when competing priorities arose. One example of such a trade-off was the choice to implement an auto-launch feature. This feature was designed to simplify the user experience by reducing potential friction when accessing the dashboard during clinical visits.^9^ While this user-centric approach was beneficial for ease of use, it introduced challenges in tracking usage, as passive viewing could not be recorded in audit logs. Despite this limitation, we considered it a worthwhile trade-off because it prioritized removing barriers to utilization, ultimately benefiting both clinicians and patients.

Careful attention to human factors and workflows played a pivotal role in the successful deployment of the RA PRO dashboard within the clinic setting. Although our user testing suggested use of the dashboard would be intuitive for most clinicians and staff, we discovered a few technical quirks that required repeated troubleshooting. We were also surprised that many clinicians found integrating the dashboard into their clinical routines challenging, particularly conversations with patients about the meaning and implications of functional status. Because the deployment was in the context of a pragmatic clinical trial, we had the advantage of having staff on site to provide support to clinicians and to develop educational materials, including scripts, to assist them in effectively discussing the content of the dashboard during patient visits. Such research resources to study implementation may not be available in purely operational deployments. In addition, systematic collection of survey and qualitative data through the pragmatic trial enabled us to tailor new materials and target clinicians with lower engagement with the dashboard. Finally, implementation of robust data tracking systems served multiple purposes: 1. Audit use logs alerted our development team to any issues with the dashboard that required technical attention; 2. PRO documentation run chart reports were provided monthly to clinic leadership to inform them about the impact of the project on clinical metrics. This symbiotic relationship between the RA PRO dashboard’s development and the pragmatic clinical trial emphasizes the benefits of aligning innovative healthcare solutions with research initiatives.

The development of health IT tools such as the RA PRO dashboard in an academic health setting comes with several inherent constraints, especially in terms of funding and timelines. The nature of funding for medical researchers requires careful planning and submission of grant proposals to fund the work months or years in advance. Compliance with regulatory standards and ethical review by an institutional review board adds complexity to the development process. Maintenance of such applications poses another significant challenge for physician researchers. In this project, we encountered issues related to numerous security updates, software upgrades, and evolving EHR structures, even over a relatively short two-year period. These maintenance challenges are typical for any digital health application, particularly one tightly integrated with the EHR, involving multiple software components. For physician researchers, sustaining the effort and funding required for long-term sustainability can be problematic.^10^

Finally, the stepped wedge pragmatic trial revealed small effects on measures of shared decision making and self-efficacy over a short (1-2 year) follow up period. We observed that the intervention group showed slightly better outcomes (higher SURE, lower PROMIS4a, fewer missed medications, more BMQ necessity over concerns, lower CDAI) across all analyses, indicating generally positive effects of the dashboard, although these were not statistically significant. Several factors may account for the lack of statistical significance in our findings. First, it is possible that the assessed outcomes change gradually, and the short-term follow-up (2-3 visits post-intervention) may not have captured the full effects of the intervention. Second, our sample size may have been insufficient to detect small changes. Additionally, several outcomes, including the SURE scale and medication adherence, showed ceiling effects even before the intervention began, limiting the potential for further improvement. Further research with longer follow-up and larger sample sizes may clarify the intervention’s impact. Despite these limited findings of the trial, our qualitative evaluation of patient and clinician perceptions of the RA PRO dashboard were strongly positive. Larger and longer-term studies are needed to understand effects of this and similar dashboards on patient outcomes.

## LIST OF PUBLICATIONS AND PRODUCTS

### Published and Accepted Manuscripts

1. Ragouzeos D, Gandrup J, Berrean B, Li J, Murphy M, Trupin L, Yazdany J, Schmajuk G. “Am I OK?” using human centered design to empower rheumatoid arthritis patients through patient reported outcomes. Patient Educ Couns. 2019 Mar;102(3):503–510. doi: 10.1016/j.pec.2018.10.016. Epub 2018 Oct 28. PMID: 30446358; PMCID: PMC6421089.30446358
2. Liu LH, Garrett SB, Li J, Ragouzeos D, Berrean B, Dohan D, Katz PP, Barton JL, Yazdany J, Schmajuk G. Patient and clinician perspectives on a patient-facing dashboard that visualizes patient reported outcomes in rheumatoid arthritis. Health Expect. 2020 Aug;23(4):846–859. doi: 10.1111/hex.13057. Epub 2020 Apr 9. PMID: 32270591; PMCID: PMC7495065.32270591
3. Nasrallah C, Wilson C, Hamblin A, Young C, Jacobsohn L, Nakamura MC, Gross A, Matloubian M, Ashouri J, Yazdany J, Schmajuk G. Using the Technology Acceptance Model to Assess Clinician Perceptions and Experiences with a Rheumatoid Arthritis outcomes Dashboard: Qualitative Study. In Press, BMC Medical Informatics and Decision Making.
4. Liu LH, Garrett SB, Li J, Ragouzeos D, Berrean B, Dohan D, Katz PP, Barton JL, Yazdany J, Schmajuk G. Patient and clinician perspectives on a patient-facing dashboard that visualizes patient reported outcomes in rheumatoid arthritis. Health Expect. 2020 Aug;23(4):846–859. doi: 10.1111/hex.13057. Epub 2020 Apr 9. PMID: 32270591; PMCID: PMC7495065.32270591
5. Izadi Z, Schmajuk G. Towards the patient-centred care of rheumatoid arthritis. Nat Rev Rheumatol. 2022 Jul;18(7):367–368. doi: 10.1038/s41584-022-00794-4. PMID: 35596082.35596082
6. Karp N, Yazdany J, Schmajuk G. Peer Support in Rheumatic Diseases: A Narrative Literature Review. Patient Prefer Adherence. 2023 Oct 2;17:2433–2449. doi: 10.2147/PPA.S391396. PMID: 37808273; PMCID: PMC10557966.37808273

### Manuscripts under review

1. Gabriela Schmajuk, Catherine Nasrallah, Beth Berrean, Jonathan Prugh, Cherish Wilson, Alicia Hamblin, Cammie Young, Lindsay Jacobsohn, Julia Kay, Jing Li, Emma Kersey, Meera Subash, Sara Murray, Jinoos Yazdany. A step-by-step roadmap for the development and deployment of an EHR sidecar application to track patient outcomes in rheumatoid arthritis. Under Review. Submitted March 21, 2024.

### Manuscripts in preparation

1. Catherine Nasrallah, Cherish Wilson, Alicia Hamblin, Christine Hariz, Jing Li, Cammie Young, Jinoos Yazdany, Gabriela Schmajuk. Benefits and limitations of using rheumatoid arthritis- patient reported outcome measures dashboard in clinical practice with patients: A mixed-methods study.
2. Gabriela Schmajuk, Jing Li, Catherine Nasrallah, Alicia Hamblin, Christine Hariz, Cherish Wilson, Emma Kersey, Cammie Young, Lindsay Jacobsohn, Julia Kay, Mary Nakamura, Andrew Gross, Beth Berrean, Jonathan Prugh, Sara Murray, Steve Shiboski, Jinoos Yazdany. Evaluation of a new EHR side-car application to display RA outcomes during clinic visits: a stepped-wedge cluster randomized trial.

### Abstracts presented at the American College of Rheumatology Annual Meeting

1. Nasrallah, C., Wilson, C., Hamblin, A., Jacobsohn, L., Young, C., Nakamura, M., Gross, A., Ashouri, J., Matloubian, M., Yazdany, J., Schmajuk, G. Using the Technology Acceptance Model to Assess Physician Perceptions and Experiences Using the Rheumatoid Arthritis-Patient-Reported Outcomes Dashboard: Mixed-Methods Study [abstract]. Arthritis Rheumatol. 2023; 75 (suppl 9). https://acrabstracts.org/abstract/using-the-technology-acceptance-model-to-assess-physician-perceptions-and-experiences-using-the-rheumatoid-arthritis-patient-reported-outcomes-dashboard-mixed-methods-study/
2. Wilson, C., Nasrallah, C., Hamblin, A., Jacobsohn, L., Young, C., Nakamura, M., Gross, A., Ashouri, J., Dietz, B., Matloubian, M., Yazdany, J., Schmajuk, G. Patient Perspectives on the Usability of a Rheumatoid Arthritis Patient-reported Outcomes Electronic Health Record-based Dashboard: A Mixed-Methods Study [abstract]. Arthritis Rheumatol. 2023; 75 (suppl 9). https://acrabstracts.org/abstract/patient-perspectives-on-the-usability-of-a-rheumatoid-arthritis-patient-reported-outcomes-electronic-health-record-based-dashboard-a-mixed-methods-study/
3. Jacobsohn, L., Kersey, E., Li, J., Nasrallah, C., Wilson, C., Young, C., Young, C., Hamblin, A., Yazdany, J., Schmajuk, G. Analyzing User Log Data to Track Provider Use of an EHR-based Dashboard for Rheumatoid Arthritis Outcomes [abstract]. Arthritis Rheumatol. 2023; 75 (suppl 9). https://acrabstracts.org/abstract/analyzing-user-log-data-to-track-provider-use-of-an-ehr-based-dashboard-for-rheumatoid-arthritis-outcomes/
4. Young, C., Montgomery, A., Nasrallah, C., Jacobsohn, L., Barton, J., Murray, S., Yazdany, J., & Schmajuk, G. Development, Implementation, and Usability Testing of a New Rheumatoid Arthritis Patient Reported Outcomes EHR-based Dashboard: A Mixed-Method Study. Arthritis Rheumatol. 2022; 74 (suppl 9). https://acrabstracts.org/abstract/development-implementation-and-usability-testing-of-a-new-rheumatoid-arthritis-patient-reported-outcomes-ehr-based-dashboard-a-mixed-method-study/

### Presentations

1. On August 25, 2023, Dr. Schmajuk provided a presentation entitled: “Pragmatic Trial of an EHR Application to Display Real-time PRO Data: Successes and Challenges” to the NIH pragmatic trials collaboratory: https://rethinkingclinicaltrials.org/news/grand-rounds-august-25-2023-pragmatic-trial-of-an-ehr-application-to-display-real-time-pro-data-successes-and-challenges-gabriela-schmajuk-md-ms/

### Training/Education materials

1. Patient educational materials: We created a patient information sheet, distributed at each appointment, using plain language to explain the meaning of different PROs collected and clarifying the purpose of completing PRO forms at each visit. This aimed to increase patient understanding of RA outcomes and encourage completion of PRO surveys before appointments.
2. Training materials and in-service teaching for clinic staff (nurses and medical assistants): The training covered the meaning of different PRO measures, highlighted the importance of collecting them, provided strategies to improve their collection, and offered scripts on how to discuss PROs with patients. The goal was to increase clinical staff knowledge in this area, with the hope that it would motivate their collection of PROs, thereby increasing the amount of data in the EHR.
3. Informational handouts for clinicians: We shared information on PRO outcomes, scoring methods, and interpretation guidelines.

## REFERENCES

1 Sittig DF, Murphy DR, Smith MW, Russo E, Wright A, Singh H. Graphical display of diagnostic test results in electronic health records: a comparison of 8 systems. J Am Med Inform Assoc. 2015 Jul;22(4):900–4. PMCID: PMC448227525792704
2 Leonardsen AL, Hardeland C, Helgesen AK, Grøndahl VA. Patient experiences with technology enabled care across healthcare settings- a systematic review. BMC Health Serv Res. 2020 Aug 24;20(1):779. doi: 10.1186/s12913-020-05633-4. PMID: 32838784; PMCID: PMC7446109.32838784
3 Lavallee DC, Chenok KE, Love RM, Petersen C, Holve E, Segal CD, Franklin PD. Incorporating patient-reported outcomes into health care to engage patients and enhance care. Health Aff (Millwood). 2016 Apr;35(4):575–82. doi: 10.1377/hlthaff.2015.1362. PMID: 27044954.27044954
4 Dixon, William G.; Michaud, Kaleb. Using technology to support clinical care and research in rheumatoid arthritis. Current Opinion in Rheumatology 30(3):p 276–281, May 2018. | DOI: 10.1097/BOR.0000000000000485 29369089
5 Hammam N, Izadi Z, Li J, Evans M, Kay J, Shiboski S, Schmajuk G, Yazdany J. The Relationship Between Electronic Health Record System and Performance on Quality Measures in the American College of Rheumatology’s Rheumatology Informatics System for Effectiveness (RISE) Registry: Observational Study. JMIR Med Inform. 2021 Nov 12;9(11):e31186. doi: 10.2196/31186. PMID: 34766910; PMCID: PMC8727049.34766910
6 Curtis JR, Sharma P, Arora T, . Physicians’ explanations for apparent gaps in the quality of rheumatology care: results from the US Medicare Physician Quality Reporting System. Arthritis care & research. 2013;65(2):235–243. PMCID: PMC368754022556118
7 Ziegenfuss, Jeanette Y. PhD1; Grossman, Elizabeth S. MPH2; Solberg, Leif I. MD2; Chrenka, Ella A. MS2; Werner, Ann BS2; Asche, Stephen E. MA2; Norton, Christine K. MA3; Nelson, Andy MPH2; Reams, Megan OT4; Whitebird, Robin R. PhD5. Is the Promise of PROMs Being Realized? Implementation Experience in a Large Orthopedic Practice. American Journal of Medical Quality 37(6):p 489–494, November/December 2022. | DOI: 10.1097/JMQ.0000000000000079 36314931
8 Solomon DH, Losina E, Lu B, Zak A, Corrigan C, Lee SB, Agosti J, Bitton A, Harrold LR, Pincus T, Radner H, Yu Z, Smolen JS, Fraenkel L, Katz JN. Implementation of Treat-to-Target in Rheumatoid Arthritis Through a Learning Collaborative: Results of a Randomized Controlled Trial. Arthritis Rheumatol. 2017 Jul;69(7):1374–1380. doi: 10.1002/art.40111. Epub 2017 May 31. PMID: 28512998; PMCID: PMC5489379.28512998
9 Neprash HT, Vock DM, Hanson A, . Effect of Integrating Access to a Prescription Drug Monitoring Program Within the Electronic Health Record on the Frequency of Queries by Primary Care Clinicians: A Cluster Randomized Clinical Trial. JAMA Health Forum. 2022;3(6):e221852. Published 2022 Jun 5. doi:10.1001/jamahealthforum.2022.1852 35977248
10 Petersen C, Smith J, Freimuth RR, Goodman KW, Jackson GP, Kannry J, Liu H, Madhavan S, Sittig DF, Wright A. Recommendations for the safe, effective use of adaptive CDS in the US healthcare system: an AMIA position paper. J Am Med Inform Assoc. 2021 Mar 18;28(4):677–684. doi: 10.1093/jamia/ocaa319. PMID: 33447854; PMCID: PMC7973467.33447854