# References

1 Eden AR, Simpson MJ, De La Mare J, Jabbarpour Y, Gerteis JS, Shoemaker-Hunt S. AHRQ’s National Center for Excellence in Primary Care Research (NCEPCR): A New Home for Primary Care Research. Annals of Family Medicine [Internet]. 2025 May 1;23(3):262. Available from: http://www.annfammed.org/content/23/3/262.abstract 40425477
2 Glossary. [cited 2025 Apr 4]; Available from: https://psnet.ahrq.gov/glossary-0
3 Lark ME, Kirkpatrick K, Chung KC. Patient Safety Movement: History and Future Directions. J Hand Surg Am. 2018 Feb;43(2):174–8.29421067
4 Guide to Improving Patient Safety in Primary Care Settings by Engaging Patients and Families [Internet]. Rockville, MD: Agency for Healthcare Research and Quality; 2018 Jul. Available from: https://www.ahrq.gov/patient-safety/reports/engage.html
5 Schiff G, Hall KK, Fitall E. Patient Safety in Primary Care. Patient Safety in Primary Care [Internet]. 2020 Jan 31 [cited 2025 Apr 4]; Available from: https://psnet.ahrq.gov/perspective/patient-safety-primary-care
6 Mossburg SE DP, O’Malley, P., McNellis, B., Chew, E. Primary Care and Patient Safety: Opportunities at the Interface [Internet]. 2022 [cited 2025 Mar 27]. Available from: https://psnet.ahrq.gov/perspective/primary-care-and-patient-safety-opportunities-interface
7 Basics of Quality Improvement [Internet]. [cited 2025 Apr 10]. Available from: https://www.aafp.org/family-physician/practice-and-career/managing-your-practice/quality-improvement-basics.html
8 Quality Measurement and Quality Improvement [Internet]. [cited 2025 Apr 11]. Available from: https://www.cms.gov/medicare/quality-initiatives-patient-assessment-instruments/mms/quality-measure-and-quality-improvement-
9 Kiran T, Ramji N, Derocher MB, Girdhari R, Davie S, Lam-Antoniades M. Ten tips for advancing a culture of improvement in primary care. BMJ Quality & Safety [Internet]. 2019 Jul 1 [cited 2025 Apr 10];28(7):582–7. Available from: https://qualitysafety.bmj.com/content/28/7/582
10 Hughes RG. Tools and Strategies for Quality Improvement and Patient Safety. In: Hughes RG, editor. Patient Safety and Quality: An Evidence-Based Handbook for Nurses [Internet]. Rockville (MD): Agency for Healthcare Research and Quality (US); 2008 [cited 2025 Apr 10]. (Advances in Patient Safety). Available from: http://www.ncbi.nlm.nih.gov/books/NBK2682/
11 Health Systems Research [Internet]. [cited 2025 Apr 10]. Available from: https://www.ahrq.gov/healthsystemsresearch/index.html
12 What is Health Services Research? [Internet]. Academy Health; [cited 2025 Apr 10]. Available from: https://academyhealth.org/sites/default/files/what_is_health_services_research_one-pager_0.pdf
13 Institute of Medicine (US) Committee on Health Services Research: Training and Work Force Issues; Thaul S, Lohr KN, Tranquada RE, editors. A WORKING DEFINITION OF HEALTH SERVICES RESEARCH. In: Health Services Research: Opportunities for an Expanding Field of Inquiry: An Interim Statement [Internet]. Washington, D.C.: National Academies Press; 1994. Available from: https://www.ncbi.nlm.nih.gov/books/NBK231502/
14 Healthcare Research and Quality Act of 1999 [Internet]. [cited 2025 Apr 4]. Available from: https://www.ahrq.gov/policymakers/hrqa99a.html
15 About Learning Health Systems [Internet]. [cited 2025 Apr 10]. Available from: https://www.ahrq.gov/learning-health-systems/about.html
16 National Healthcare Quality & Disparities Reports [Internet]. [cited 2025 Apr 8]. Available from: https://www.ahrq.gov/research/findings/nhqrdr/index.html
17 National Academies of Sciences Engineering, and Medicine. Implementing High-Quality Primary Care: Rebuilding the Foundation of Healthcare [Internet]. 2021. Available from: https://www.nationalacademies.org/our-work/implementing-high-quality-primary-care
18 What is Integrated Behavioral Health? [Internet]. [cited 2025 Apr 3]. Available from: https://integrationacademy.ahrq.gov/about/integrated-behavioral-health
19 Van Beek K, Duchemin S, Gersh G, Pettigrew S, Silva P, Luskin B. Counseling and Wellness Services Integrated with Primary Care: A Delivery System That Works. Perm J [Internet]. 2008 [cited 2025 Apr 3];12(4):20–4. Available from: https://www.ncbi.nlm.nih.gov/pmc/articles/PMC3037136/ 21339917
20 Research and Action Institute [Internet]. [cited 2025 Apr 3]. Exploring Barriers to Mental Health Care in the U.S. Available from: https://www.aamcresearchinstitute.org/our-work/issue-brief/exploring-barriers-mental-health-care-us
21 Davenport S, Darby B, Gray TJ, Spear C. Access across America: State-by-state insights into the accessibility of care for mental health and substance use disorders [Internet]. Milliman; 2023 Dec. Available from: https://www.inseparable.us/AccessAcrossAmerica.pdf
22 Schrager S. Family Practice Management. 2021 [cited 2025 Apr 3]. Integrating Behavioral Health Into Primary Care. Available from: https://www.aafp.org/pubs/fpm/issues/2021/0500/p3.html
23 American Medical Association [Internet]. 2022 [cited 2025 Apr 3]. Lack of access to evidence-based mental health care poses grave threat. Available from: https://www.ama-assn.org/about/leadership/lack-access-evidence-based-mental-health-care-poses-grave-threat
24 National Academies of Sciences, Engineering, and Medicine Engineering, Health and Medicine Division, Board on Health Care Services, Committee on Implementing High-Quality Primary Care, Robinson SK, Meisnere M, . Digital Health and Primary Care. In: Implementing High-Quality Primary Care: Rebuilding the Foundation of Health Care [Internet]. National Academies Press (US); 2021 [cited 2025 Apr 4]. Available from: https://www.ncbi.nlm.nih.gov/books/NBK571817/
25 Health IT and Digital Health [Internet]. [cited 2025 Apr 4]. Available from: https://www.ahrq.gov/ncepcr/research/health-it/index.html
26 Patient-Centered Healthcare | Agency for Healthcare Research and Quality [Internet]. [cited 2025 Apr 4]. Available from: https://www.ahrq.gov/topics/patient-centered-healthcare.html
27 2023 National Healthcare Quality and Disparities Report [Internet]. Rockville, MD: Agency for Healthcare Research and Quality; 2023 Dec [cited 2025 Apr 4]. Report No.: AHRQ Publication No. 23(24)-0091-EF. Available from: https://www.ahrq.gov/sites/default/files/wysiwyg/research/findings/nhqrdr/2023-qdr-appendixb-measure-category-6.pdf
28 Jabbarpour Y, Petterson, S., Jetty, A., Byun, H. The Health of US Primary Care: A Baseline Scorecard Tracking Support for High-Quality Primary Care [Internet]. Robert Graham Center; 2023 Feb. Available from: https://www.graham-center.org/content/dam/rgc/documents/publications-reports/reports/milbank-baseline-scorecard.pdf
29 Bazemore AW PS. US Primary Care Workforce Growth: A Decade of Limited Progress, and Projected Needs Through 2040. Journal of General Internal Medicine [Internet]. 2025;40(2):339–46. Available from: https://link.springer.com/content/pdf/10.1007/s11606-024-09121-x.pdf 39443342
30 Stressed Out and Burned Out: The Global Primary Care Crisis [Internet]. [cited 2025 Apr 2]. Available from: https://www.commonwealthfund.org/publications/issue-briefs/2022/nov/stressed-out-burned-out-2022-international-survey-primary-care-physicians?utm_source=pocket_saves
31 Berg S. American Medical Association. 2024 [cited 2025 Mar 26]. Physician burnout rate drops below 50% for first time in 4 years. Available from: https://www.ama-assn.org/practice-management/physician-health/physician-burnout-rate-drops-below-50-first-time-4-years
32 Taking Action Against Clinician Burnout: A Systems Approach to Professional Well-Being [Internet]. Washington, DC: National Academy of Sciences, Engineering, and Medicine; 2019. Available from: https://nap.nationalacademies.org/catalog/25521/taking-action-against-clinician-burnout-a-systems-approach-to-professional
33 Family Physician Burnout, Well-Being, and Professional Satisfaction (Position Paper) [Internet]. [cited 2025 Mar 27]. Available from: Available from: https://www.aafp.org/about/policies/all/family-physician-burnout.html
34 Edwards ST, Marino M, Balasubramanian BA, Solberg LI, Valenzuela S, Springer R, . Burnout Among Physicians, Advanced Practice Clinicians and Staff in Smaller Primary Care Practices. Journal of General Internal Medicine [Internet]. 2018 Dec;33(12):2138–46. Available from: https://pmc.ncbi.nlm.nih.gov/articles/PMC6258608/ 30276654
35 Role of Community Health Workers [Internet]. [cited 2025 Apr 11]. Available from: https://www.nhlbi.nih.gov/education/heart-truth/CHW/Role
36 Topic: Public Health [Internet]. [cited 2025 Apr 11]. Available from: https://www.ahrq.gov/topics/public-health.html
37 Allen LN, Rechel B, Alton D, Pettigrew LM, McKee M, Pinto AD, . Integrating public health and primary care: a framework for seamless collaboration. BJGP Open [Internet]. 2024 Dec 1;8(4):BJGPO.2024.0096. Available from: http://bjgpopen.org/content/8/4/BJGPO.2024.0096.abstract 39532486
38 Abt Global and The Agency for Healthcare Research and Quality. The Agency for Healthcare Research and Quality’s Investments in Primary Care Research for 2021 and 2022 [Internet]. Rockville, MD: Agency for Healthcare Research and Quality; 2024 Feb. Available from: https://www.ahrq.gov/sites/default/files/publications2/files/ncepcr-investments-2021-2022.pdf
39 Advancing Patient-Centered Care for People Living With Multiple Chronic Conditions [Internet]. [cited 2025 Apr 11]. Available from: https://www.ahrq.gov/patient-safety/settings/long-term-care/resource/multichronic/mcc.html
40 Older Adults [Internet]. [cited 2025 Jul 16]. Available from: https://odphp.health.gov/healthypeople/objectives-and-data/browse-objectives/older-adults