# Primary Care Grants and Resources

In this section we share information about AHRQ’s primary care investments in FYs 2023 and 2024, including grants with active funding and initiatives and resources released during this period. This information is organized into the nine key topic areas listed below.

In the tables throughout this section, we include short summaries for each of the 104 unique AHRQ primary care research grants. While most of the grants presented in this report align with multiple topic areas, we have included each grant in the topic area that best matches the main focus of the work under that grant (as determined by the Abt team). The topic area sections are presented in order of greatest number of grants to fewest.

Topic area sections are:

- Patient Safety
- Practice and Quality Improvement
- Healthcare Systems and Infrastructure
- Health Disparities
- Behavioral Health and Substance Use Disorders
- Digital Healthcare
- Person-Centered Care
- Primary Care Workforce
- Public Health and Community Integration

Grant tables in each topic area section are organized by subtopic, and the grants in each table are presented in alphabetical order by the title of the grant. Grant titles in the tables hyperlink to additional information about the grant (including publications) on the NIH RePORTER website.

## Patient Safety

AHRQ defines patient safety as “freedom from accidental or preventable injuries produced by medical care.”^(2)^ Patient safety gained national attention in the late 1990’s with the publication of the Institute of Medicine’s report To Err is Human, which estimated that thousands of patients die each year due to preventable errors in U.S. hospitals.^(3)^ High-quality primary care plays a critical role in patient safety because it ensures that care is comprehensive, coordinated, and continuous. As described in The Guide to Improving Patient Safety in Primary Care Settings by Engaging Patients and Families (https://www.ahrq.gov/sites/default/files/wysiwyg/professionals/quality-patient-safety/patient-family-engagement/pfeprimarycare/pfepc-fullguide-final508.pdf), AHRQ lays out how the relationships developed in the primary care setting among clinicians, patients, and families are essential for ensuring that care is centralized, safe, and effective.^(4)^ Primary care helps to encourage active communication between clinicians and patients, as well as coordination and collaboration within and across clinical teams. This active communication and coordination prevents diagnostic delays and medication errors, avoids fragmentation of care, and facilitates transitions in care, thus reducing avoidable hospital admissions and readmissions.^(5,6)^

AHRQ funds research and implementation projects through its Center for Quality Improvement and Patient Safety (CQuIPS) to understand approaches to deliver safer patient care. This section provides information about patient safety grants, initiatives, and resources that are focused on primary care.

### Grants

Across the AHRQ primary care research grants with active funding in FYs 2023 and 2024, 18 focus mainly on patient safety. This includes eight R01 grants (Research Projects), seven R18 grants (Research Demonstration and Dissemination), and three K08 grants (Mentored Clinical Scientist Development Awards).

An additional five grants with some focus on patient safety are described in other topic area sections, including one in Practice and Quality Improvement, one in Health Disparities, one in Digital Healthcare, one in Person-Centered Care, and one in Primary Care Workforce.

We summarize the 18 grants focused on patient safety below, organized by subtopic. The subtopics are:

- Medication Safety and Management
- Improving Diagnostic Accuracy
- Diagnostic Safety and Quality
- Predictive Tools for Patient Safety
- Safety of Telehealth and E-Health

#### Medication Safety and Management

Seven grants focus on reducing adverse drug events and inappropriate use of antibiotics and improving medication management.

[image] Improving Eauitable Access to Penicillin Allergv De-Labeling (https://reporter.nih.gov/project-details/10829821) (R01); PIs: Kimberly Gold Blumenthal; Alysse Gail Wurcel; Organization: Tufts Medical Center; Grant Start Date: May 1, 2023; Aims to understand the barriers and facilitators to removing inaccurate penicillin allergy labeling in primary care, which has been shown to decrease exposure to suboptimal antibiotics and has the potential to reduce multi-drug resistance and healthcare-associated infections. Long term, the study aims to increase implementation of penicillin allergy de-labeling in primary care and reduce infection-associated health disparities.
Improving Medication Safety for Medically Complex Children with mHealth Across Caregiving Networks (https://reporter.nih.gov/project-details/10830249) (R18); PIs: Ryan J. Coller; Nicole E. Werner; Organization: University of Wisconsin – Madison; Grant Start Date: May 2, 2022; Develops an app (MedS@HOME) to improve medication safety for children with medical complexity who may receive care in pediatric primary care and from specialists. The app supports standardized medication management across caregivers to increase administration accuracy and reduce medication-related adverse events.; Webinar icon Learn more about this study in a recent NCEPCR webinar: Innovative Use of Technology in Primary Care Delivery. (https://www.ahrq.gov/ncepcr/about/pcr-webinar-series/innovative-use.html)
Integrating Pharmacists into an Automated Discharge Process to Promote Comprehensive Medication Management (https://reporter.nih.gov/project-details/10626125) (R18); PI: Joel F. Farley; Organization: University of Minnesota; Grant Start Date: July 1, 2021; Evaluates the implementation of pharmacist-provided comprehensive medication management to coordinate care for high-need/high-cost patients when they transition between the hospital and primary care. In this program, a health information exchange’s automated electronic alert system notifies primary care clinics when patients need pharmacist-provided comprehensive medication management after a hospital visit.
[image] Optimizing the Clinical Management of Polypharmacy for Children with Medical Complexity (https://reporter.nih.gov/project-details/10809676) (R01); PI: James A. Feinstein; Organization: University of Colorado – Denver; Grant Start Date: April 1, 2023; Assesses the effectiveness of a pharmacist-led Pediatric Medication Therapy Management intervention compared with usual care (e.g., primary care or specialist provider) to reduce medication-related problems (such as inappropriate therapy, undertreated symptoms, or adverse drug events) for children with medical complexity in an outpatient complex care program.
[image] Patient-Centered Stewardship to Improve Antibiotic Use in Ambulatory Care (https://reporter.nih.gov/project-details/10928220) (R01); PIs: Jeffrey A. Linder; Julia E. Szymczak; Organization: Northwestern University at Chicago; Grant Start Date: September 30, 2023; Aims to reduce antibiotic overuse in ambulatory care settings, including primary care, by understanding and addressing the concerns and behaviors of patients known to frequently use antibiotics inappropriately. The mixed-methods study includes controlled cohort studies to develop patient categories by antibiotic usage; interviews and qualitative analyses to identify the social and behavioral factors that influence antibiotic use among patients with frequent inappropriate antibiotic use; and develops and tests a patient-centered behavioral nudge intervention to reduce inappropriate antibiotic use among these patients.
[image] Patient-Driven Medication Safety Learning Laboratory in Care Transitions (https://reporter.nih.gov/project-details/10916491) (R18); PIs: Ranjit Singh; Heui-Yen Chen; David Jacobs; Organization: State University of New York at Buffalo; Grant Start Date: September 1, 2023; Aims to develop a learning lab for older adult patients and caregivers to decrease risk for medication harm during transitions of care. The learning lab encourages patients and their caregivers to work with their healthcare team to achieve safer medication use during this vulnerable time, which leads to the design, development, and testing of scalable human-centered interventions across the transition of care continuum, including in primary care.
Reducing Use of Antibiotics Without a Prescription Among Outpatients in a Safety Net Healthcare System (https://reporter.nih.gov/project-details/10609827) (R01); PIs: Barbara Wells Trautner; Larisa Grigoryan; Organization: Baylor College of Medicine; Grant Start Date: July 1, 2019; Examines factors at the patient, healthcare system, and clinician encounter levels that predict use of nonprescribed antibiotics by patients seen in safety net primary care clinics, who are predominantly uninsured and often have low incomes. Develops a communication tool to help clinics guide their patients toward safer antibiotic use.

#### Improving Diagnostic Accuracy

These five grants examine various approaches to improving diagnostic accuracy.

Averting Diagnostic Error Through Improved Recognition of Child Abuse (https://reporter.nih.gov/project-details/10911109) (K08); PI: Irit R. Rasooly; Organization: Children’s Hospital of Philadelphia; Grant Start Date: September 30, 2022; Uses electronic health record (EHR) data and systems analysis to develop clinical decision support (CDS) strategies that can identify and help diagnose child abuse in primary care settings. The research team is using EHR data to detect and validate markers of physical abuse to help identify children experiencing abuse; using EHR simulations to identify abuse-related diagnostic errors; and working to develop feasible, acceptable, and appropriate CDS strategies for improved child abuse detection and diagnosis.; Learn more about this study in a NCEPCR Impact Story: Advancing Primary Care Research Careers (https://www.ahrq.gov/sites/default/files/wysiwyg/ncepcr/about/impact-stories/research-careers.pdf)
[image] Complexity, Incidence, and Costs Related to Delayed Diagnosis of Venous Thromboembolism in Urban and Rural Primary and Urgent Care Settings (https://reporter.nih.gov/project-details/11020773) (R01); PIs: Patricia C. Dykes; Jin Chen; Organization: Brigham and Women’s Hospital; Grant Start Date: September 1, 2024; Develops an advanced, data-driven electronic clinical quality measure to measure timely, delayed, and missed venous thromboembolism (VTE) diagnoses in ambulatory and urgent care settings. Uses EHR data and stakeholder expertise to understand risk factors for VTE diagnostic errors, disparities in care, and health outcomes. Develops artificial intelligence and statistical learning tools to identify and address vulnerabilities in workflows to help reduce delayed and missed VTE diagnoses.
[image] A Randomized Controlled Trial of a Diagnostic Stewardship Intervention to Reduce Inappropriate Antibiotic Use for Urinary Tract Infections in Primary Care (https://reporter.nih.gov/project-details/10894077) (R01); PIs: Larisa Grigoryan; Barbara Wells Trautner; Organization: Baylor College of Medicine; Grant Start Date: August 1, 2023; Tests the effectiveness of a diagnostic stewardship intervention to improve the accuracy of urinary diagnostic testing by reducing the contamination of urine samples leading to inappropriate antibiotic use in primary care. Develops, assesses, and iteratively improves patient education on proper midstream clean-catch urine sample collection strategies, with input from stakeholders to address known barriers to accurate urine sample collection.
[image] Time for Better Diagnosis: Measuring Outcomes, Stress and Time proposal (MOST) (https://reporter.nih.gov/project-details/11023260) (R01); PI: Gordon David Schiff; Organization: Brigham and Women’s Hospital; Grant Start Date: September 30, 2024; Analyzes the relationships between diagnostic quality (processes, communication with patients, and outcomes), time allotted for clinical visits, and clinician stress. Comparing primary care encounters from one clinic that allows 20 minutes per visit with one that allows 30 minutes per visit, the research team solicits patient feedback about processes and outcomes for diagnostic visits; uses EHR timestamp data to assess visit time and outcomes; and conducts qualitative analysis of diagnostic patient/clinician conversations during visits based on artificial intelligence–generated EHR notes.
A Turn-Key EHR Simulation Program to Reduce Diagnostic Error in Ambulatory Care (https://reporter.nih.gov/project-details/10690451) (R18); PIs: Jeffery A. Gold; Raj M. Ratwani; Organization: Oregon Health & Science University; Grant Start Date: September 30, 2019; Develops a library of validated EHR-based simulations to improve diagnostic safety in ambulatory care. The research team is using a combination of administrative and claims data to identify diagnoses at risk for diagnostic error in ambulatory care settings and the EHR use errors associated with those diagnostic errors. Uses this data to develop simulations for five ambulatory care settings, including primary care, and validates the use of the simulation activities as a training tool to change EHR use patterns and reduce diagnostic errors.

#### Diagnostic Safety and Quality Centers

These two grants are part AHRQ’s Diagnostic Safety Centers of Excellence (https://www.ahrq.gov/patient-safety/diagnostic-excellence-grants/index.html) grant initiative, which had the goal of collectively developing systems, measures, and new technology solutions to improve diagnostic safety and quality.

DECODE: Diagnostic Excellence Center on Diagnostic Error (https://reporter.nih.gov/project-details/10914020) (R18); PIs: Ramin Khorasani; Ronilda Lacson; Organization: Brigham and Women’s Hospital; Grant Start Date: September 30, 2022; Develops a Diagnostic Center of Excellence to reduce failures in timely performance of clinically necessary diagnostic imaging exams and interpretation errors. The team implements IT-enabled functions and workflows to enhance a clinical dashboard with improved EHR integration and monitoring as well as learning capabilities to help reduce diagnostic errors and health disparities across settings, including primary care. In addition, this project provides opportunities for peer learning to reduce interpretive errors and convenes a team of clinicians to develop consensus recommendations for the management of lung, prostate, pancreatic, and adrenal cancers and embed the recommendations into the EHR.
Diagnostic Safety Center for Advancing E-Triggers and Rapid Feedback Implementation (DISCOVERI) (https://reporter.nih.gov/project-details/10918176) (R18); PI: Hardeep Singh; Organization: Baylor College of Medicine; Grant Start Date: September 30, 2022; Develops a center that supports the implementation of surveillance and feedback systems to improve diagnostic safety in healthcare organizations. The center works to accelerate the uptake of electronic trigger (e-trigger) tools, which mine large sets of clinical and administrative data to identify signals for likely adverse events. E-trigger algorithms can efficiently identify patterns of care indicating missed or delayed diagnoses in primary care as well as other settings.

#### Predictive Tools for Patient Safety

These two studies use innovative approaches to understand and improve patient safety.

[image] Improving Risk Prediction for Children Seeking Emergency Medical Services (EMS) Care with Nonemergent Complaints (https://reporter.nih.gov/project-details/10983593) (K08); PI: Caleb Ward; Organization: Children’s Research Institute; Grant Start Date: August 1, 2024; Refines and pilot tests the Pediatric Observation Priority Score (POPS) for use by Emergency Medical Services (EMS) technicians as a risk assessment tool to identify which children can be safely managed without going to an emergency department (ED). First, the study identifies factors associated with under triage of children who are not transported by EMS to an ED; then works to optimize the acceptability, appropriateness, and feasibility of the POPS tool with clinical end-users; and finally, uses simulations and field pilot studies to assess the refined POPS tool. Once validated, the POPS will be useful to study EMS innovations for caring for children, including treatment in pace, telemedicine, and integration of primary care.
[image] Machine-Learning Prediction Model for Personalized Urinary Tract Infection Care in Children (https://reporter.nih.gov/project-details/10983858) (K08); PI: Hsin-Hsiao Scott Wang; Organization: Boston Children’s Hospital; Grant Start Date: July 1, 2024; Aims to reduce the risk of renal injury from febrile urinary tract infection in children by developing and implementing prediction modeling to assist primary care clinicians and families in determining the most optimal timing for a voiding cystourethrogram. Develops the machine-learning prediction model using a combination of pediatric practice data and advice from experts in related fields and then piloted to further adapt the model to maximize adoption and sustainability.

#### Safety of Telehealth and E-Health

Two studies examine safety issues related to the use of telehealth and e-health.

[image] Evaluating Diagnostic Decision Support Systems for Patients Requiring Urgent Primary or Emergency Care or with Stroke (https://reporter.nih.gov/project-details/10877007) (R01); PI: Hamish SF. Fraser; Organization: Brown University; Grant Start Date: July 1, 2023; Evaluates the safety, usability, and diagnostic and triage accuracy of a symptom checker smartphone app used by patients to identify when urgent primary or emergency care is needed, such as a transient ischemic attack or stroke. Tests the symptom checker app with patients to assess impact on their intentions to seek care, collects patient feedback on the app’s usability, compares diagnostic and triage accuracy of the app compared with the assessment of a treating physician, and evaluates the impact on patient decision making of two options for presenting diagnosis and triage information through the app. Uses data collected in a community setting to evaluate the influence of patient characteristics, including age, sex, race, ethnicity, country, and socioeconomic group on the presentation of symptoms.
[image] Safe and Equitable Telehealth for Chronic Conditions (SafE-T C2) Learning Laboratory (https://reporter.nih.gov/project-details/10923892) (R18); PIs: Raj M. Ratwani; Ethan A. Booker; Organization: MedStar Health Research Institute; Grant Start Date: September 30, 2022; Aims to develop the SafE-T C2 Learning Laboratory, which will address issues related to chronic conditions, health disparities, and primary care. The laboratory will help identify safety issues for telehealth patients (particularly patients with chronic conditions) and guide the development and implementation of solutions. The laboratory uses the socio-technical system engineering framework, which underscores that technology, policies, processes, and people all play a role in patient safety issues. Implements identified solutions across multiple outpatient clinics.

### Initiatives and Resources

A wide range of patient safety–related resources and information can be found on AHRQ’s Patient Safety and Quality Improvement (https://www.ahrq.gov/patient-safety/index.html) webpage. PSNet (https://psnet.ahrq.gov/), a searchable resource with information and tools related to patient safety is still available online – but is not currently funded, so the last update was in March 2025. The focus of these AHRQ resources is broader than primary care, however, many resources available on these webpages are relevant for primary care settings. Below we share information about several primary care-related patient safety materials that were initially released or updated in 2023 and 2024.

This image shows the logo of the Team Strategies & Tools to Enhance Performance & Patient Safety (TeamSTEPPS®) toolkit.

In 2023, AHRQ updated Team Strategies & Tools to Enhance Performance & Patient Safety (TeamSTEPPS^®^). TeamSTEPPS^®^ 3.0 (https://www.ahrq.gov/teamstepps-program/updated/index.html) is an evidence-based set of tools designed to improve patient outcomes by improving the communication and teamwork skills of healthcare teams and emphasizing patient engagement. Updated materials include welcome guides, curriculum materials with multiple modules, a pocket guide, patient videos, and training videos. AHRQ now offers the TeamSTEPPS^®^ training free of charge, with continuing education units available for a fee.

Diagnostic Safety Issue Briefs

Three recently published Diagnostic Safety Issue Briefs (https://www.ahrq.gov/diagnostic-safety/resources/issue-briefs.html) are specifically relevant to primary care:

- Reimagining Healthcare Teams: Leveraging the Patient-Clinician-AI Triad to Improve Diagnostic Safety (https://www.ahrq.gov/diagnostic-safety/resources/issue-briefs/dxsafety-reimagining-healthcare-teams.html). Provides a framework for how patients and clinicians can safely and effectively use artificial intelligence and machine learning when making diagnostic decisions.
- Patient Experience as a Source for Understanding the Origins, Impact, and Remediation of Diagnostic Errors:
  - Volume 1: Why Patient Narratives Matter (https://www.ahrq.gov/diagnostic-safety/resources/issue-briefs/dxsafety-patients-source-understanding-dx-error-vol1.html). Highlights the importance of collecting patient perspectives about the impacts of diagnosis-related events to help build clinician understanding and reduce patient harm.
  - Volume 2: Eliciting Patient Narratives (https://www.ahrq.gov/diagnostic-safety/resources/issue-briefs/dxsafety-patients-source-understanding-dx-error-vol2.html). Discusses the importance of using rigorous methods to collect patient experiences about diagnosis-related events and how this information can be used to advance learning about the diagnostic process.

Improving Healthcare Safety by Engaging Patients and Families

This report (https://www.ahrq.gov/sites/default/files/wysiwyg/patient-safety/highlights/ps-project-highlights-pfe.pdf) summarizes research findings from across 53 AHRQ grants related to the importance of patient and family engagement to improve healthcare safety and quality.

## Practice and Quality Improvement

Practice improvement and quality improvement are both terms used to describe the systematic approach of assessing practice performance and making changes to standardize and improve care.^(7,8)^ Often these terms are used interchangeably; however, practice improvement is often used to refer to efforts to improve care within an individual practice whereas quality improvement is used to refer to broader, system-wide efforts. Practice improvement and quality improvement efforts can be used in primary care to reduce inefficiency and preventable errors, improve patient outcomes, and simultaneously increase patient and clinician satisfaction.^(9,10)^

Effectively implementing quality improvement (QI) in primary care requires disseminating the latest evidence to practices, as well as building practice capacity to implement changes to care based on that evidence. AHRQ funds patient-centered outcomes research to generate new evidence, as well as dissemination and implementation (D&I) research about how to translate and use evidence-based practices in clinical settings – including primary care.

### Grants

Across AHRQ primary care research grants with active funding in FYs 2023 and 2024, 17 focus mainly on practice and quality improvement. This includes nine U18 grants (Research Demonstration / Cooperative Agreement), two R18 grants (Research Demonstration and Dissemination Projects), two R03 grants (Small Research Projects), two R13 grants (Conference), one R01 grant (Research Project), and one K01 award (Research Career Program).

Another 30 grants have some focus on practice and quality improvement and are described in other topic area sections, including six in Health Disparities, six in Patient Safety, five in Person-Centered Care, four in Digital Healthcare, four in Behavioral Health and Substance Use Disorders, three in Healthcare Systems and Infrastructure, and two in Public Health and Community Integration.

We summarize the 17 grants focused on practice and quality improvement below, organized by subtopic. The subtopics are:

- Managing Urinary Incontinence
- Building State Capacity for QI
- Evaluating Practice Improvements
- Improving Care and Prevention for Cardiovascular Disease
- Conference Grants

#### Managing Urinary Incontinence

These five cooperative agreements are part of AHRQ’s EvidenceNOW: Managing Urinary Incontinence (https://www.ahrq.gov/evidencenow/projects/urinary/index.html) program. See more about the overall EvidenceNOW initiative and learn about recent resources developed as a part of this program here.

Bridging Community-based Continence Promotion and Primary Care (https://reporter.nih.gov/project-details/10773045) (U18); PIs: Joan Marie Neuner; Heidi Wendell Brown; Kathryn E. Flynn; Organization: Medical College of Wisconsin; Grant Start Date: February 1, 2022; Aims to increase the proportion of patients who are screened and offered treatment for urinary incontinence (UI) in 50 primary care practices. The intervention, called UI Assist, includes screening, education, and evidence-based treatment. The research team compares implementation of UI Assist alone or in combination with partnership building to help practices overcome barriers to intervention implementation.
Empowering Women and Providers for Improved Care of Urinary Incontinence: EMPOWER Study (https://reporter.nih.gov/project-details/10764257) (U18); PIs: Adonis K. Hijaz; Goutham Rao; Organization: University Hospitals of Cleveland; Grant Start Date: February 1, 2022; Uses an integrated, multilevel approach to address key barriers to diagnosing and managing urinary incontinence in primary care. Implements the approach across a large network of primary care practices, including large-scale screening, empowering patients to discuss urinary incontinence with their clinicians, clinician education and training, practice facilitation through nurse navigation, and a “chatbot” to support patient self-management. The project also implements a system-based strategy for streamlined referrals and treatment.; Webinar icon Learn more about this study in a recent NCEPCR webinar: Research on Women’s Health in Primary Care (https://www.ahrq.gov/ncepcr/about/pcr-webinar-series/womens-health-research.html).
Identify, Teach, and Treat (IT2): Automating Clinical Decision Pathways for the Care of Women (https://reporter.nih.gov/project-details/10763374) (U18); PIs: Stephen Persell; Kimberly Sue Kenton; Organization: Northwestern University at Chicago; Grant Start Date: February 1, 2022; This project’s multilevel implementation strategy aims to improve care for urinary incontinence for women in primary care through systematic and equitable screening, supporting patient-centered decision making for selecting treatment options, and accelerating the uptake of evidence-based nonsurgical treatment modalities. This project takes place in the largest health system in Illinois, with 65 primary care practices and 327 primary care physicians.
Improving Primary Care Understanding of Resources and Screening for Urinary Incontinence to Enhance Treatment (PURSUIT) (https://reporter.nih.gov/project-details/10770363) (U18); PIs: Alayne Denise Markland; Elizabeth Camille Vaughan; Organization: University of Alabama at Birmingham; Grant Start Date: February 1, 2022; Aims to improve access for women Veterans in the southeastern United States to evidence-based, nonsurgical treatment for urinary incontinence. The study compares the effectiveness of the interactive treatment modality with or without additional urinary incontinence clinical expertise delivered via telehealth in 62 primary care practices that treat women Veterans. Participating practices receive practice facilitation support, training, and health information technology assistance. Researchers explore women Veterans’ and clinicians’ perceptions of remote urinary incontinence treatment to advise future scalability.
A Practice-Based Intervention to Improve Care for a Diverse Population of Women with Urinary Incontinence (https://reporter.nih.gov/project-details/10764898) (U18); PI: Jennifer Tash Anger; Organization: University of California, San Diego; Grant Start Date: February 1, 2022; Aims to improve the quality of urinary incontinence care provided to a diverse population of women in primary care, with the goals of improving care and reducing the need for specialty care. Includes three Southern California medical groups (a total of 60 clinics) in a practice-based incontinence intervention led by a “clinical champion dyad” comprising a primary care clinician and a urologist/urogynecologist for each medical group. Includes clinician education and performance feedback, electronic decision support, patient education from dedicated advanced practice clinicians, and an electronic referral service.

#### Building State Capacity for QI

These four grants fund the state-based cooperatives from AHRQ’s EvidenceNOW: Building State Capacity (https://www.ahrq.gov/evidencenow/projects/state/index.html) program. See more about the overall EvidenceNOW initiative and learn about recent resources developed as a part of this program here.

Achieving Outstanding Cardiovascular Health Outcomes for All Ohioans: A Statewide Cardiovascular Health Collaborative (Cardio-OH) (https://reporter.nih.gov/project-details/10543057) (U18); PIs: Shari Danielle Bolen; Aleece Caron; Organization: Case Western Reserve University; Grant Start Date: January 1, 2021; Expands a nascent statewide cardiovascular health collaborative in Ohio and establishes a sustainable external QI support infrastructure in the state. The project also implements and evaluates a QI intervention for heart health codesigned with primary care practices.
The Alabama Cardiovascular Cooperative: Supporting Cardiovascular Risk Reduction in Primary Care (https://reporter.nih.gov/project-details/10542719) (U18); PI: Andrea L. Cherrington; Organization: University of Alabama at Birmingham; Grant Start Date: January 1, 2021; Establishes the Alabama Cardiovascular Cooperative to coordinate statewide efforts to improve cardiovascular risk and reduce disparities. Additionally, implements a heart health improvement project in 60 primary care clinics throughout Alabama to improve rates of blood pressure control and screening for smoking status.
Healthy Hearts for Michigan (HH4M): Providing Support to Improve Heart Health and Help Reduce CVD Disparities by Engagement with Primary Care Practices (https://reporter.nih.gov/search/pZUeNnUOMUSa1YW8TZF_XQ/project-details/10542723) (U18); PIs: Anya Day; Theresa L. Walunas; Organization: Altarum Institute; Grant Start Date: January 1, 2021; Establishes a statewide cooperative in Michigan to provide QI support to help primary care practices implement interventions to improve hypertension management and tobacco cessation. These efforts are coupled with optimization of health information technology and telehealth approaches to address barriers to access in rural parts of the state.
Tennessee Health Network: Implementing Patient-Centered Practices in Primary Care to Improve Cardiovascular Health (https://reporter.nih.gov/project-details/10577725) (U18); PI: James E. Bailey; Organization: University of Tennessee Health Science Center; Grant Start Date: March 1, 2021; Establishes the Tennessee Heart Health Network (THHN), which leverages existing infrastructure to identify and implement evidence-based interventions to improve quality of care for cardiovascular disease in primary care across the state. THHN specifically targets hypertension control and smoking cessation to help reduce disparities in cardiovascular outcomes.

#### Evaluating Practice Improvements

Four grants test the implementation and uptake of approaches to improve quality in primary care.

Badge icon [image] Bridges to Primary Care: Transforming Postpartum Primary Care Coordination for People with Chronic Conditions (https://reporter.nih.gov/project-details/11023517) (R01); PIs: Mark Allen Clapp; Jessica Lee Cohen; Organization: Massachusetts General Hospital; Grant Start Date: September 30, 2024; Develops and evaluates an intervention to strengthen coordination and transition of obstetric and primary care for postpartum patients. The intervention consists of default scheduling for primary care visits, tailored nudge messages to patients, ongoing care recommendations sent to the primary care clinician, and giving a summary of after-pregnancy recommendations to the patient.; Webinar icon Learn more about this study in a recent NCEPCR webinar: Factors That Impact Perinatal Care Experiences and Outcomes (https://www.ahrq.gov/ncepcr/about/pcr-webinar-series/perinatal-care-experience.html).
[image] A New Combination of Evidence-Based Interventions to Improve Primary Care Diagnostic Safety and Efficiency: A Stepped Wedge Cluster RCT (https://reporter.nih.gov/project-details/10928800) (R18); PI: Eric J. Thomas; Organization: University of Texas Health Science Center Houston; Grant Start Date: September 30, 2022; Assesses the implementation of a bundle of evidence-based interventions (EBIs) designed to reduce missed abnormal laboratory tests in primary care practice using a stepped wedge cluster randomized controlled trial (RCT). The EBIs to be implemented include automated abnormal test result detection and tracking, including clinical pathologists on primary care teams, and using nurse navigators to engage patients in the diagnostic process. The research team plans to examine the impact of the EBIs on patient safety and diagnostic efficiency; assess the acceptability, appropriateness, cost, and sustainability of the interventions; and identify facilitators and barriers to implementation.
[image] Prediction of Practice Change in Primary Care Following Guideline Updates (https://reporter.nih.gov/project-details/11054271) (R03); PI: Nathaniel David Hendrix; Organization: American Board of Family Medicine; Grant Start Date: September 30, 2024; Aims to help clinical guideline developers predict and improve the uptake and potential impact of primary care–relevant clinical guideline updates. The research team uses change-point analysis to assess predictors of guideline-concordant practice change for four recent clinician guideline updates, and then uses a multi-level model with patient, clinician, and practice site characteristics to predict the time to practice change. The team also uses latent class analysis to develop phenotypes of clinicians based on their responses to the four guideline updates to identify patterns of practice change. Finally, the team develops market segmentation and the individualized educational outreach to improve the efficiency and impact of dissemination activities based on the phenotypes.
Badge icon [image] Receipt, Disparities, and Impact of Early Primary Care Follow-Up After Pediatric Critical Illness (https://reporter.nih.gov/project-details/10739168) (R03); PI: Erin Fitzgerald Carlton; Organization: University of Michigan at Ann Arbor; Grant Start Date: July 1, 2023; Uses national multi-payer data to measure how often children have a primary care follow-up visit within seven days after a pediatric intensive care unit stay after experiencing a critical illness. The study also assesses disparities in primary care follow-up by patient age, comorbidities, and socioeconomic status and examines whether receipt of timely follow-up is associated with reduced 90-day acute healthcare utilization.

#### Improving Care and Prevention for Cardiovascular Disease

Two studies focused on QI for cardiovascular disease, in particular.

Adapting Guideline Implementation to Local Environments (AGILE) in Primary Care After Telehealth Expansion (https://reporter.nih.gov/project-details/10813022) (K01); PI: Edmond Ramly; Organization: Trustees of Indiana University; Grant Start Date: April 8, 2022; Aims to develop a customizable toolkit for implementing cardiovascular disease guidelines in primary care after telehealth expansion. The toolkit includes a menu of options to help practices address specific local barriers without requiring the engagement of an expert for a costly tailoring process.
Improving Recognition and Management of Hypertension in Youth: Comparing Approaches for Extending Effective CDS for Use in a Large Rural Health System (https://reporter.nih.gov/project-details/10876919) (R18); PIs: Elyse Olshen Kharbanda; Catherine Pastorius Benzinger; Organization: HealthPartners Institute; Grant Start Date: September 30, 2020; Compares high- and low-intensity interventions to implement an electronic health record–linked clinical decision support in rural primary care practices to provide evidence-based clinical care recommendations for blood pressure management in youth.; Magnifying glass icon Learn more about this study in a Primary Care Research Profile: Identifying and Managing Hypertension Among Rural Youth (https://www.ahrq.gov/sites/default/files/wysiwyg/ncepcr/about/profiles/profile_kharbanda.pdf)

#### Conference Grants

AHRQ funded two conferences to share evidence-based practices among primary care clinicians.

[image] National Practice-Based Research Network Conferences 2023 to 2025 (https://reporter.nih.gov/project-details/10809656) (R13); PI: Allison Cole; Organization: NAPCRG (North American Primary Care Research Group); Grant Start Date: April 1, 2023; Supports the NAPCRG’s 19th, 20th, and 21st meetings of practice-based research networks (PBRNs). Includes funding to help promote the meeting and then support the convening itself. Support includes coordinating, managing, and evaluating the event and then disseminating the results. The PBRN conferences help build the skills and knowledge of clinicians, researchers, and community partners in evidence-based research to improve the health of the U.S. population, healthcare delivery systems, and the quality of primary healthcare.
[image] Strategic Planning for the Next Generation of Research on Pediatric Eating Disorders in Primary Care (https://reporter.nih.gov/project-details/10752866) (R13); PI: Christina Tortolani; Organization: Rhode Island College; Grant Start Date: September 30, 2023; Supports a research development conference to advance evidence-based care of pediatric eating disorders in primary care. Various presentations and breakout groups contribute to the development of a “research roadmap,” outlining priorities such as education needs and practical screening, diagnosis, and treatment decisions. Although primary care clinicians are often the first contact of families of children suffering from eating disorders, they are often undertrained in the assessment and management of these conditions. This conference is a first step in getting primary care clinicians the support they need to confidently identify, manage, and treat pediatric eating disorders. (See Eating Disorder Resources for Clinicians and Patients (https://integrationacademy.ahrq.gov/news-and-events/news/eating-disorder-resources-clinicians-and-patients) for additional information on this topic and the conference proceedings).

### Initiatives and Resources

AHRQ shares evidence-based resources for Practice Improvement (https://www.ahrq.gov/practiceimprovement/index.html), including tools, toolkits, and trainings. These resources include EvidenceNOW Tools for Change (https://www.ahrq.gov/evidencenow/tools/index.html), a searchable database of tools that primary care practices can use to implement QI activities. Primary care-relevant resources released in 2023 and 2024 are described below.

This image shows the logo of EvidenceNOW.

EvidenceNOW (https://www.ahrq.gov/evidencenow/index.html) projects use the same model (https://www.ahrq.gov/evidencenow/model/index.html) to provide external support to help primary care practices implement new evidence into care. The first EvidenceNOW project, Advancing Heart Health (https://www.ahrq.gov/evidencenow/projects/heart-health/index.html), ended in 2018, but three EvidenceNOW projects continued to be active during 2023 and 2024:

- EvidenceNOW: Managing Urinary Incontinence. (https://www.ahrq.gov/evidencenow/projects/urinary/index.html) Helped primary care practices implement evidence-based, nonsurgical treatments for urinary incontinence in women. AHRQ funded five grantees and a contract to support a learning community and program-wide evaluation. Project materials released in 2023 and 2024 include:
  - Managing Urinary Incontinence for Women in Primary Care: Environmental Scan Report Update for the Managing Urinary Incontinence Initiative (https://www.ahrq.gov/sites/default/files/wysiwyg/evidencenow/projects/urinary/mui-environmental-scan-oy1report.pdf)
  - Tools and Resources to Help Improve Urinary Incontinence Care for Women (https://www.ahrq.gov/evidencenow/projects/urinary/resources.html)
  - Webinar: Managing Urinary Incontinence in Primary Care: Sharing Progress and Resources from AHRQ’s EvidenceNOW Initiative (https://www.ahrq.gov/evidencenow/projects/urinary/webinars/110623.html)
  - Webinar: Implementing Urinary Incontinence Management in Primary Care: Case Studies from AHRQ’s EvidenceNOW Program (https://www.ahrq.gov/evidencenow/projects/urinary/webinars/management.html)
- EvidenceNOW: Building State Capacity (https://www.ahrq.gov/evidencenow/projects/state/index.html). Focused on building state capacity and infrastructure to support primary care practices with implementing evidence-based heart health interventions and decreasing health disparities. AHRQ funded four grantees and a technical assistance and evaluation center. Project-wide materials released in 2023 and 2024 are included below (see EvidenceNOW: Tools and Resources (https://www.ahrq.gov/evidencenow/tools/search/index.html) for additional materials developed by the state cooperatives):
  - Developing and Sustaining State-Based Infrastructure to Support Primary Care Quality Improvement - A How-To Guide (https://www.ahrq.gov/sites/default/files/wysiwyg/evidencenow/projects/state/how-to-guide/how-to-guide.pdf)
  - Building State Cooperatives for Healthcare Improvement: Meeting Summary (https://www.ahrq.gov/evidencenow/projects/state/meeting-summary-cooperatives/index.html)
  - The Second Interim Evaluation Report can be found with other reports here (https://www.ahrq.gov/sites/default/files/wysiwyg/evidencenow/building-capacity/en-bsc-interim-report-2.pdf).
- EvidenceNOW: Managing Unhealthy Alcohol Use (https://www.ahrq.gov/evidencenow/projects/alcohol/index.html). Worked to increase screening for unhealthy alcohol use in primary care, followed by a brief intervention and referral to treatment when indicated. AHRQ funded six grants as well as a Resource Center and evaluation contract. Project materials released in 2023 and 2024 include:
  - Environmental Scan Final Report: Managing Unhealthy Alcohol Use in Primary Care (https://integrationacademy.ahrq.gov/sites/default/files/2023-08/unhealthy-alcohol-use-environmental-scan-report.pdf?)
  - Webinar: National Evaluation and Grantee Findings from the AHRQ EvidenceNOW Managing Unhealthy Alcohol Use in Primary Care Initiative (https://www.ahrq.gov/evidencenow/projects/alcohol/webinar-uau-evaluation.html)

Practice-Based Research Network (PBRN) Resources

AHRQ funds an annual PBRN conference (https://www.napcrg.org/conferences/pbrn/pastconferences/overview/) through the North American Primary Care Research Group (NAPCRG) and continues to host resources (https://www.ahrq.gov/ncepcr/communities/pbrn/index.html) to support PBRNs, including a listserv and registry. In 2024, NCEPCR launched a learning series (https://www.ahrq.gov/ncepcr/communities/pbrn/learning-series/index.html) to support and promote the work of PBRNs. The learning series includes:

- An E-Learning Course: Building a Newer PBRN (https://www.ahrq.gov/downloads/ncepcr/communities/pbrn/learning-series/building-newer-pbrn/index.html#/). This self-paced e-learning course shares information and resources that are useful for audiences looking to set up a new PBRN or build an existing one.
- Two Webinars:
  - Managing and Growing an Established PBRN (https://www.ahrq.gov/ncepcr/communities/pbrn/learning-series/managing-growing.html)
  - Highlighting and Promoting the Value of PBRNs (https://www.ahrq.gov/ncepcr/communities/pbrn/learning-series/highlighting-promoting.html)

This is a photo of primary care researcher, Beth Bortz.

AHRQ’s initial investment in Heart of Virginia Healthcare (https://www.ahrq.gov/evidencenow/projects/heart-health/about/cooperatives/virginia.html), a regional cooperative participating in the EvidenceNOW: Advancing Heart Health program, led to additional work and investments by other funders – resulting in sustained efforts to improve the quality of primary care in Virginia.

Read a NCEPCR Impact Story to learn more about the Virginia Task Force on Primary Care, led by Beth Bortz: Bridging Gaps and Uniting Partners to Improve Primary Care in the Commonwealth of Virginia (https://www.ahrq.gov/sites/default/files/wysiwyg/ncepcr/about/impact-stories/bridging-gaps.pdf).

## Healthcare Systems and Infrastructure

Health systems research (also known as health services research) examines how healthcare is organized, financed, and delivered to patients – and whether the care provided is affordable, safe, and effective.^(11–13)^ As the foundation of a high quality and cost effective healthcare system, a focus on primary care in health services research is especially important. Findings from health systems research can inform changes in healthcare processes, benefits, and policy to improve the safety, quality, person-centeredness, and accessibility of care.^(11)^

AHRQ is the only federal department tasked with supporting health systems research, including how “healthcare services are organized, delivered, and financed and the interaction and impact of these factors on the quality of patient care.”^(14)^ AHRQ’s efforts in this area have been estimated to have saved American healthcare systems more than $12 billion.^(12)^

Health systems research is a broad term that applies to primary care studies described throughout this report. In this section, we describe grants and resources that specifically focus on how healthcare organizations (i.e., practices, health centers, and health systems) structure and pay for primary care, and how changes in these areas affect patient care and health outcomes. This includes studies that examine various models of care, different organizational structures and ownership arrangements, health financing approaches and payment reform models, and the development of learning health systems. Learning health systems are defined by AHRQ as healthcare organizations where “…internal data and experience are systematically integrated with external evidence, and that knowledge is put into practice.”^(15)^

### Grants

Across the AHRQ primary care research grants with active funding in FYs 2023 and 2024, 15 focus mainly on healthcare systems and infrastructure. This includes nine R01 grants (Health Services Research Projects Program), three R03 grants (Small Research Projects), two P30 grants (Research Program Projects and Centers), and one K08 grant (Mentored Clinical Scientist Development Award).

There are an additional 14 grants with some focus on healthcare systems and infrastructure, which are described in other topic area sections, including five in Healthcare Disparities, three in Digital Healthcare, two in Patient Safety, one in Behavioral Health and Substance Use Disorders, one in Practice and Quality Improvement, one in Primary Care Workforce, and one in Public Health and Community Integration.

We summarize the 15 grants focused on healthcare systems and infrastructure below, organized by subtopic. The subtopics are:

- Care Models
- Healthcare Financing and Payment
- Healthcare Ownership and Organization
- Learning Health Systems

#### Care Models

Six studies examined various care models.

Examining Payment and Delivery Model Impacts on Health Equity Using Novel Quasi-Experimental Causal Inference Methods (https://reporter.nih.gov/project-details/10840334) (R01); PI: Laura Hatfield; Organization: Harvard Medical School; Grant Start Date: August 1, 2022; Examines the impact of the Comprehensive Primary Care Plus (CPC+) model on health outcomes for Black Medicare beneficiaries, including an examination of the variation in responses to CPC+ within subgroups by patient demographics and Medicaid eligibility status.
[image] PIC-TRFS: A Randomized Trial of a Multicomponent Intervention for ICU Survivors and Caregivers (https://reporter.nih.gov/project-details/10856394) (R01); PI: Leslie Page Scheunemann; Organization: University of Pittsburgh at Pittsburgh; Grant Start Date: June 1, 2024; Tests, via a randomized controlled trial, the Post-Intensive Care Transitional Care, Rehabilitation, and Family Support (PIC-TRFS) model that aims to improve outcomes and prevent rehospitalizations for intensive care unit (ICU) survivors. The intervention supports the health and social care needs of patients in the six months following a critical illness hospitalization as they transition from the hospital setting to the home setting with healthcare support from home health and primary care.
Badge icon [image] Primary Care Needs for Patients with Vascular Anomalies: Improving Continuity of Care and Care Coordination in Rare Diseases (https://reporter.nih.gov/project-details/10929502) (R03); PI: Anna M. Kerr; Organization: Ohio University – Athens; Grant Start Date: September 15, 2023; Aims to understand facilitators and barriers to high-quality care coordination and continuity of care for patients with vascular anomalies in primary care, specifically those living in rural areas. The study includes interviews with vascular anomalies specialists, patients, and their caregivers, as well as pediatricians.
Social Networks in Medical Homes and Impact on Patient Care and Outcomes (https://reporter.nih.gov/project-details/10548173) (R01); PI: Lusine Poghosyan; Organization: Columbia University Health Sciences; Grant Start Date: February 1, 2019; Uses social network analysis to examine how staff connections affect team performance and patient outcomes within primary care practices using the Patient Centered Medical Home model. This study aims to show how to facilitate teamwork and identify the most effective team attributes to assure best quality of care and outcomes particularly for patients with chronic diseases.
Tele-Recovery: Engaging Stakeholders to Adapt and Pilot Test a Scalable Transitional Rehabilitation Intervention for Older, Rural ICU Survivors (https://reporter.nih.gov/project-details/10706523) (K08); PI: Leslie Page Scheunemann; Organization: University of Pittsburgh at Pittsburgh; Grant Start Date: September 30, 2019; Tests a transitional care model, TeleRecovery, where a nurse practitioner and occupational therapist deliver telehealth-based rehabilitation services for older adults and their caregivers in rural areas after a transfer from the intensive care unit to home. The TeleRecovery teams work with home health providers to implement the patients’ care plans until they are well enough to be managed in primary care.
[image] Testing a Cardiovascular Ambulatory Rapid Evaluation for Patients with Chest Pain (CARE-CP) (https://reporter.nih.gov/project-details/10812424) (R01); PI: Simon A. Mahler; Organization: Wake Forest University Health Sciences; Grant Start Date: April 1, 2023; Assesses the use of Cardiovascular Ambulatory Rapid Evaluation (CARE) as an alternative to hospitalization for those experiencing chest pain. The CARE strategy consists of a follow-up within 72 hours of being discharged from the emergency department using medical management of cardiovascular risk factors and determining whether further cardiac testing is necessary. The study aims to understand whether CARE safely reduces healthcare utilization and whether patients prefer CARE to traditional hospitalization.

#### Healthcare Financing and Payment

Four studies investigate the impacts of health financing and payment reform models.

Analysis of a Tiered Clinic Cost-Sharing Health Insurance Benefit Design (https://reporter.nih.gov/project-details/10889071) (R01); PI: Bryan E. Dowd; Organization: University of Minnesota; Grant Start Date: August 5, 2022; Evaluates a long-running tiered cost-sharing system where Minnesota State employees select a primary care clinic that is responsible for coordinating their care, including referrals to specialists, hospital care, and use of pharmaceuticals. Clinics are assessed on their risk-adjusted total cost of care; cost savings are shared with patients, incentivizing them to select care coordination through lower-cost clinics. This study specifically explores clinic leaders’ perceptions of the system, how they have responded to being included in the system, and the barriers they face to practicing more efficiently.
[image] Evaluations of Increasing State Investments in Primary Care: Effects on Health Care Spending, Utilization, and Quality (https://reporter.nih.gov/project-details/10882745) (R01); PI: Zirui Song; Organization: Harvard Medical School; Grant Start Date: April 1, 2024; Examines the effect of policy changes aimed at increasing primary care spending in four leading states (Rhode Island, Oregon, Delaware, and Colorado). For Oregon, Delaware, and Colorado, uses public and private claims data to analyze changes in healthcare spending, utilization, and quality associated with newly enacted models. For Rhode Island, extends a prior evaluation of short-term effects on commercial insurer spending to include a full decade after policy changes, to identify potential long-term impacts, including utilization and quality outcomes. Also assesses spillover effects on Medicare and Medicaid populations in all four states. Findings from this study can be used to help inform other states considering similar legislation.; Magnifying glass icon Learn more about this study in a Primary Care Research Profile: Understanding the Impacts of State Efforts to Increase Primary Care Spending (https://www.ahrq.gov/sites/default/files/wysiwyg/ncepcr/about/profiles/profile_song.pdf)
[image] Impact of Payment Methods on Service Delivery at Community Health Centers (https://reporter.nih.gov/project-details/10793584) (R03); PI: Avi Dor; Organization: The George Washington University; Grant Start Date: March 1, 2023; Aims to explore the effects of changes in Medicaid reimbursement on the utilization and costs of Community Health Center (CHC)–provided services and the financial health of CHCs in general. Uses data from the National Association of Community Health Centers (NACHC) combined with the federal Uniform Data System (UDS).
Primary Care Involvement in End Stage Renal Disease Seamless Care Organizations (ESCOs) and the Quality and Costs of Care for Patients on Chronic Dialysis (https://reporter.nih.gov/project-details/10767240) (R01); PIs: Vahakn B. Shahinian; Richard A. Hirth; John Malcolm Hollingsworth; Organization: University of Michigan at Ann Arbor; Grant Start Date: April 1, 2020; Studies end stage renal disease Seamless Care Organizations (ESCO), including whether ESCOs affect the frequency and quality of primary care provider (PCP) and nephrologist interactions, involvement of PCPs on financial and clinical outcomes, and outcomes for patients in ESCO versus other payment models including Accountable Care Organizations and Medicare Shared Savings Plans.

#### Healthcare Ownership and Organization

Three studies looked at how healthcare institutions are structured and how ownership type affects care.

Badge icon [image] Assessing the Impact of Health System Ownership on Fulfilling the Vision of High-Quality Primary Care and Whole Health (https://reporter.nih.gov/project-details/11057145) (R03); PI: E. Marshall Brooks; Organization: Virginia Commonwealth University; Grant Start Date: September 1, 2024; Assesses the impact of health system ownership of primary care practices on key elements of high-quality primary care and whole health and describes the contextual factors that may affect care using a mixed-methods design.; Webinar icon Learn more about this study in a recent NCEPCR webinar: The Impact of Consolidation and Ownership on Primary Care. (https://www.ahrq.gov/ncepcr/about/pcr-webinar-series/consolidation-ownership.html)
[image] Health Systems and High-Need Populations: The Effect of Vertical Integration on Utilization, Spending, and Quality for Medically Complex Patients (https://reporter.nih.gov/project-details/10809663) (R01); PIs: Amelia Bond; Dhruv Khullar; Organization: Weill Medical College of Cornell University; Grant Start Date: April 1, 2023; Assesses whether health system expansion improves care for medically complex Medicare patients, particularly those in acquired primary care practices. The study aims to understand what health system strategies and characteristics contribute to successes or failures in improving quality of care.; Webinar icon Learn more about this study in a recent NCEPCR webinar: The Impact of Consolidation and Ownership on Primary Care. (https://www.ahrq.gov/ncepcr/about/pcr-webinar-series/consolidation-ownership.html)
[image] Private Equity Acquisitions in Primary Care: Effects on the Medicare Program (https://reporter.nih.gov/project-details/10907588) (R01); PIs: Jane Mingjia Zhu; Zirui Song; Organization: Oregon Health & Science University; Grant Start Date: September 1, 2023; Aims to understand how private equity (PE) acquisition of primary care practices changes provider behavior (including utilization of low-value services and diagnostic coding intensity) as well as how PE acquisition affects the health and healthcare of Medicare beneficiaries. Using Medicare data, the study examines how PE ownership affects provider behavior under the different financial incentives of traditional Medicare and Medicare Advantage and estimates the effects on care quality and patient outcomes.; Webinar icon Learn more about this study in a recent NCEPCR webinar: The Impact of Consolidation and Ownership on Primary Care. (https://www.ahrq.gov/ncepcr/about/pcr-webinar-series/consolidation-ownership.html)

#### Learning Health Systems

The two grants described below are part of the Learning Health System Embedded Scientist Training and Research (LHS StaR) Centers (https://www.ahrq.gov/pcor/ahrq-pcor-trust-fund-training-projects/pcor-lhs.html).

[image] Southwest Safety Net Embedded Scientist Training and Research (SSNE-STaR) Center (https://reporter.nih.gov/project-details/10815487) (P30); PIs: William J. Riley; Michael White; Organization: Arizona State University – Tempe Campus; Grant Start Date: January 1, 2024; Creates a learning health system model to support training, professional development, and rapid-cycle implementation skills of physicians and researchers embedded in safety net healthcare organizations in Arizona. The SSNE-STaR is a collaboration among inpatient and ambulatory care health systems, federally qualified health centers, Tribal health centers, community partners, and other stakeholders – with primary care, maternal care, and disabilities as research priorities. There are multiple components of this research center grant, including an Administrative Core (https://reporter.nih.gov/search/4wBsbLDDsk2rHaVyjJTk-Q/project-details/10815488) (PI: William Riley).
[image] Washington Learning Health System Embedded Scientist Training and Research Center (WA LHS E-STAR Center) (https://reporter.nih.gov/project-details/10814015) (P30); PIs: Paula Lozano; James D. Ralston; Organization: Kaiser Foundation Research Institute; Grant Start Date: January 1, 2024; Establishes the WA LHS E-STAR Center to provide researchers with training and mentorship focused on increasing participatory research, formalized stakeholder engagement, and health equity. The Center’s goals include building new research-healthcare partnerships, training seven early-career researchers, and embedding learning health systems research in participating primary care organizations. There are multiple components of this research center grant, including an Administrative Core (https://reporter.nih.gov/search/UAmcJ0TjwUWk7GvStF1T0w/project-details/11004304), a Research Education Core (https://reporter.nih.gov/search/UAmcJ0TjwUWk7GvStF1T0w/project-details/11004307), and a Research and Data Analysis Core (https://reporter.nih.gov/search/UAmcJ0TjwUWk7GvStF1T0w/project-details/11004311) (all with Paula Lozano as PI).

### Initiatives and Resources

AHRQ maintains the Medical Expenditure Panel Survey (https://meps.ahrq.gov/mepsweb/) (MEPS), a large national secondary data source for measuring how people use and pay for medical care in the United States. MEPS includes survey data from individuals, medical providers, and employers. Although MEPS includes information about a broad set of medical services beyond primary care, it is a helpful source of data for primary care researchers.

There were two primary care–relevant resources from FYs 2023 and 2024 related to Healthcare Systems and Infrastructure, described below.

Measuring Primary Healthcare Spending

This technical brief (https://effectivehealthcare.ahrq.gov/products/primary-healthcare-spending/tech-brief?_gl=1*85qqe8*_ga*MTgyMTYyMzk1OC4xNzM5MjE1NzA2*_ga_1NPT56LE7J*MTc0MzQzMTEwMi41Ni4xLjE3NDM0MzI1MTUuMC4wLjA.), developed by AHRQ’s Effective Health Care Program (https://effectivehealthcare.ahrq.gov/) and published in May 2024, presents initial steps for establishing a standardized approach for estimating spending for primary care in the United States. The authors reviewed a wide range of definitions, data sources, and approaches used across states to estimate primary care spending and identified areas of consensus and differences.

Compendium of U.S. Health Systems

Data added to AHRQ’s Compendium of U.S. Health Systems (https://www.ahrq.gov/chsp/data-resources/compendium.html) in 2024 allow researchers to explore trends in primary care. The data include information from 2022 about outpatient sites by practice type, specialty, and whether practices are in a primary care shortage area.

An interactive data visualization (https://www.ahrq.gov/data/visualizations/corporate-ownership.html) of compendium data allows users to explore information about practice ownership. Data can be filtered by state to show the proportion of practices that are independent, are part of an integrated delivery network, or have corporate ownership.

AHRQ Long COVID Care Network

AHRQ funded nine grants in September 2023 and another three in July 2024 to support existing multidisciplinary Long COVID clinics across the U.S. These grants allowed Long COVID clinics to expand access and care, develop and implement new or improved care delivery models, and foster best practices for Long COVID management. AHRQ also funded a technical assistance and evaluation contract: “Supporting and Evaluating AHRQ’s Initiative to Implement New Models of Comprehensive, Coordinated, Person-Centered Care for People with Long COVID”. Some of these grants are particularly relevant to primary care, including:

- Mid-Atlantic Pediatric Long COVID Network: Implementing Patient-Centered and Multidisciplinary Practices to Improve Pediatric Long COVID (https://reporter.nih.gov/project-details/10932338) (PI: Laura A. Malone) – Aims to expand and strengthen the Kennedy Krieger Institute Post-COVID-19 Rehabilitation Clinic to provide care to more children with long COVID. The project will educate primary care providers and community partners on the diagnosis, care, and management of children with long COVID.
- Novel Statewide Response to Post-COVID Care Delivery (https://reporter.nih.gov/project-details/10932363) (PIs: Sarah E. Jolley and Donald E. Nease) – Implements and evaluates the Colorado Multidisciplinary Translation Network (CO-MTN) to better integrate long COVID care. CO-MTN includes a community of practice, primary care practice-based research network, and a tele-education system to train healthcare providers.

More about this initiative, including profiles of the 12 grants, can be found on the AHRQ webpage for the Long COVID Care Network (https://www.ahrq.gov/coronavirus/long-covid/care-network.html).

Developing and Sustaining State-Based Infrastructure to Support Primary Care Quality Improvement

This image shows the cover of a report entitled “Developing and Sustaining State-Based Infrastructure To Support Primary Care Quality Improvement—A How-To Guide”

In 2024, AHRQ released a how-to guide (https://www.ahrq.gov/evidencenow/projects/state/how-to-guide/index.html) for developing and sustaining state-based cooperatives designed to provide external QI support for primary care practices and strengthen their capacity to deliver evidence-based, whole-person care. Drawing primarily from the experiences of AHRQ’s EvidenceNOW: Building State Capacity (https://www.ahrq.gov/evidencenow/projects/state/index.html) grantees, the guide includes effective approaches, lessons learned, and example materials. The guide is designed to be useful to groups planning or developing similar infrastructure, including programs with a focus broader than primary care.

## Health Disparities

AHRQ’s authorizing legislation, the Healthcare Research and Quality Act of 1999, requires the agency to conduct and support research, evaluations, and demonstrations focused on healthcare in both rural and inner-city areas, as well as on a range of priority populations.^(14)^ These populations were specified in the legislation to include:

- Low-income groups
- Minority groups
- Women
- Children
- The elderly
- Individuals with special healthcare needs (including individuals with disabilities and those who need chronic care or end-of-life healthcare)

The legislation also requires AHRQ to annually develop and submit to Congress a report on “disparities in healthcare delivery as it relates to racial factors and socioeconomic factors in priority populations.”^(14)^ Since then, AHRQ has published the National Healthcare Quality and Disparities Report, which shows trends in healthcare disparities by race, ethnicity, and social determinants of heath (SDOH).^(16)^

In 2021, the National Academies of Sciences, Engineering, and Medicine (NASEM) observed that greater availability of primary care is needed for better population health and more equitable outcomes.^(17)^ AHRQ has invested in a growing number of research grants focused on understanding and addressing health disparities across priority populations. This section includes a summary of AHRQ’s primary care grants and resources focused on AHRQ’s priority populations.

### Grants

Across AHRQ primary care research grants with active funding in FYs 2023 and 2024, 15 focus mainly on health disparities. This includes four R03 grants (Small Research Projects), four K01 grants (Research Career Programs), three R01 grants (Research Projects), three R18 grants (Research Demonstration and Dissemination Projects), and one K08 grant (Mentored Clinical Scientist Development Award).

Another 31 grants have some focus on health disparities and are described in other topic area sections, including seven in Practice and Quality Improvement, five in Behavioral Health and Substance Use Disorders, five in Patient Safety, four in Digital Healthcare, four in Healthcare Systems and Infrastructure, three in Primary Care Workforce, two in Person-Centered Care, and one in one in Public Health and Community Integration.

We summarize the 15 grants focused on health disparities below, organized by subtopic. The subtopics are:

- Understanding and Addressing Barriers to Care
- Dissemination and Implementation of Equity-Focused Interventions
- Innovative Approaches to Addressing Health Disparities
- Insights from Patients and Caregivers
- Costs of Care

#### Understanding and Addressing Barriers to Care

The six grants described below aim to understand and/or address barriers to care experienced by different patient populations.

[image] Assessing the Impact of Financial Incentives on Provision of Interpretive Services in Medicaid (https://reporter.nih.gov/project-details/10726438) (R03); PI: Monique Gill; Organization: Providence Health & Services – Oregon; Grant Start Date: September 30, 2023; Uses a longitudinal design to understand the impact of recently introduced financial incentives to increase access to interpretive services among Oregon’s Medicaid members with non-English language preference (NELP) across settings, including primary care. Assesses differences in use of interpretive services by setting, type of care, modality of interpretation, interpreter type, and population.
[image] Centering the Needs of Black Children in Foster Care: Healthcare Utilization and Coordinated Medical Homes (https://reporter.nih.gov/project-details/11037215) (R03); PI: Abigail Williams-Butler; Organization: Rutgers University; Grant Start Date: September 30, 2024; Examines healthcare use among Black youth in foster care and the role that coordinated medical care homes (i.e., when primary care and specialty care are provided in the same setting) play in improving their health outcomes compared with youth who receive services through multiple systems. The study uses 11 years of linked child welfare and electronic health records data along with the voices of young people in the foster care system. Results can be used to improve the health of Black youth in foster care and to potentially reduce the overall cost of healthcare among foster youth.
[image] Effects of COVID-19 Related Medicaid Policy Changes in the Marshallese COFA Migrant Population (https://reporter.nih.gov/project-details/11045169) (R01); PI: Jennifer Audrey Andersen; Organization: University of Arkansas for Medical Sciences; Grant Start Date: September 1, 2024; Assesses the impact of COVID-19 related Medicaid policy changes on healthcare access among the; Marshallese COFA (Compact of Free Association) migrant population. Actively engages the; Marshallese COFA migrant population to understand barriers and facilitators to Medicaid/healthcare access and develop community-based interventions to use of primary and preventative healthcare services.
Examining the Impact of Healthcare Systems Changes on Healthcare Use and Health Outcomes for Children in Foster Care (https://reporter.nih.gov/project-details/10885022) (R01); PI: Sarah Beal; Organization: Cincinnati Children’s Hospital Medical Center; Grant Start Date: September 30, 2022; Evaluates the impact of different delivery models on health outcomes for children in foster care and examines the factors that contribute to variations in healthcare use and health outcomes for these youth. The findings can be used to implement health delivery practice changes, often in primary care, to improve the health outcomes of these vulnerable youth.
The Effect of Rurality and the COVID-19 Pandemic on Telemedicine and Preventive Healthcare Use (https://reporter.nih.gov/project-details/10894054) (K01); PI: Annie Elizabeth Larson Organization: OCHIN, Inc.; Grant Start Date: August 1, 2022; Investigates the role of telemedicine in improving access to primary care for rural patients. The research team is looking at the frequency and type of preventive care visits, differences between urban and rural patients on uptake of telemedicine, and the effect of telemedicine on the quality and equity of care for chronic health conditions among rural and urban patients.; Webinar icon Learn more about this study in the NCEPCR webinar: Using Large Datasets for Primary Care Research (https://www.ahrq.gov/ncepcr/about/pcr-webinar-series/large-datasets.html) and the Impact Story: Advancing Primary Care Research Careers (https://www.ahrq.gov/sites/default/files/wysiwyg/ncepcr/about/impact-stories/research-careers.pdf).
[image] Understanding Primary Care Utilization and Barriers to Care Among Sexual and Racial/Ethnic Minority Populations (https://reporter.nih.gov/project-details/10793560) (R03); PI: Ning Hsieh; Organization: Michigan State University; Grant Start Date: March 1, 2023; Aims to understand primary care utilization inequalities and the barriers to care faced by sexual and racial/ethnic minority populations. The study team analyzes data from the National Health Interview Survey (2013-2020) and the Behavioral Risk Factor Surveillance System (2014-2020) to document inequities in primary care utilization among sexual and racial minoritized populations compared with their heterosexual and White counterparts and to identify unique mechanisms underlying the inequities facing each disadvantaged group.

#### Dissemination and Implementation of Equity-Focused Interventions

The three grants described below each come from the Dissemination and Implementation of Equity-Focused Evidence-Based Interventions in Healthcare Delivery Systems (https://grants.nih.gov/grants/guide/rfa-files/RFA-HS-23-002.html) grant initiative. The projects focus on prevention, screening, and managing chronic conditions, including in primary care settings.

[image] Bridging the Gap: Delivering Equitable Colorectal Cancer Screening (https://reporter.nih.gov/project-details/10933504) (R18); PI: Hannah Arem; Organization: MedStar Health Research Institute; Grant Start Date: September 30, 2023; To increase the percentage of Black and Hispanic patients who complete colorectal cancer screening, this study adapts a patient navigation intervention using the Practical, Robust Implementation and Sustainability Model (PRISM) and core health and racial equity principles. Conducts a stepped-wedged, randomized trial to roll out patient navigation and patient and clinician reminders across 15 primary care clinics (3 clinics per step, 5 six-month steps).
[image] Implementation Strategies for Self-Measured Blood Pressure Monitoring in Racially and Ethnically Diverse Populations (InS2PiRED) (https://reporter.nih.gov/search/QitnH8CUTEu1da74OIKl4A/project-details/10831792) (R18); PI: Elaine Khoong; Organization: University of California, San Francisco; Grant Start Date: September 30, 2023; Develops and evaluates both patient- and clinic-level strategies to increase implementation of self-measured blood pressure monitoring programs combined with clinical support in primary care for low-income, racially and ethnically diverse populations.; Magnifying glass icon Learn more about this study in a Primary Care Research Profile: Increasing Patients’ Self-Monitoring of Blood Pressure in Safety Net Settings (https://www.ahrq.gov/sites/default/files/wysiwyg/ncepcr/about/profiles/profile_khoong.pdf)
[image] Navigating Together for Equitable Asthma Management (Nav-TEAM) for Children in Families Who Communicate in Languages Other Than English (https://reporter.nih.gov/project-details/10928215) (R18); PIs: Lisa Ross Decamp; Meredith Parrish Fort; Organization: University of Colorado – Denver; Grant Start Date: September 30, 2023; Develops the Nav-TEAM intervention to improve asthma management in children in families who communicate in a language other than English (LOE). The research team will use community-engaged processes to tailor asthma navigation for families that communicate in LOE in primary and subspecialty pediatric pulmonary care settings at a large academic children’s health system. The team will evaluate the effectiveness of Nav-TEAM on pediatric asthma outcomes, evaluate the application of implementation strategies, and assess cost and contextual factors to support sustained implementation and scaling of the intervention.

#### Innovative Approaches to Addressing Health Disparities

The three studies below describe a range of innovative approaches to measuring and reducing health disparities in primary care.

[image] Advancing Equity in Early Childhood Developmental Screening Through Item Response Theory and User-Centered Design (https://reporter.nih.gov/project-details/10927407) (K01); PI: Kendra Liljenquist; Organization: Seattle Children’s Hospital; Grant Start Date: September 30, 2023; Aims to help address inequities in access to developmental screening for children from low-income and ethnic/racial minority families by developing a prototype for a new computer-adaptive developmental assessment to be used in primary care. The research team identifies culturally and contextually appropriate assessment items in both English and Spanish, as well as develops specifications for building a high-fidelity, computer-adaptive developmental assessment for integration into clinical care.
[image] Improving Diagnostic Equity in Ambulatory Care Settings (I.D.E.A.S.): Research to Practice (https://reporter.nih.gov/project-details/10931551) (R01); PIs: Kristen Elizabeth Miller; William J. Gallagher; Organization: MedStar Health Research Institute; Grant Start Date: September 30, 2023; Evaluates diagnostic errors in ambulatory care settings, including primary care, in the context of diagnostic equity (i.e., addressing disparities in diagnostic errors due to systemic challenges in policies and practices) and uncertainty. The study team uses decision-modeling and human factors methodologies to conceptualize and measure diagnostic errors, with the goal of designing a comprehensive framework to inform interventions aimed at reducing diagnostic inequity and improving the management of diagnostic uncertainty.
Badge icon [image] A Patient-Informed Approach to Measuring and Mitigating Inequity in Primary Care (https://reporter.nih.gov/project-details/10983591) (K01); PI: Kristina Bridges; Organization: University of Kansas Medical Center; Grant Start Date: August 1, 2024; Aims to learn how to conduct QI in primary care without exacerbating health disparities by bridging health inequities research, medical informatics, and QI and implementation science. The study team identifies healthcare quality measures using a community-informed, equity-focused approach; incorporates those measures into QI dashboards; and designs strategies to decrease health inequity using community-engaged intervention mapping.; Webinar icon Learn more about this study in a recent NCEPCR webinar: Approaches to Address the Health of Specific Patient Populations in Primary Care (https://www.ahrq.gov/ncepcr/about/pcr-webinar-series/specific-pt-populations.html).

#### Insights from Patients and Caregivers

The two studies described below aim to understand disparities in care by considering the perspectives of primary care patients and caregivers.

Badge icon [image] Compassion Disparities in Primary Care: A Mixed Methods Pilot Study (https://reporter.nih.gov/project-details/10878795) (R03); PI: Stephen Walter Trzeciak; Organization: Rowan University; Grant Start Date: July 1, 2023; Aims to understand and mediate the impacts of disparities in primary care clinicians’ compassion from the patient perspective. In a diverse population of primary care patients, the research team conducts a cross-sectional cohort study to compare anonymous, real-time, point-of-care patient assessments of clinician compassion to identify differences across racial, ethnic, and socioeconomic groups. The team tests whether clinician compassion mediates patient distrust of the healthcare system and uses qualitative analyses to identify clinician behaviors that effectively communicate compassion from the patient perspective for each population group studied.
[image] Developing and Piloting an Intervention to Reduce HPV Vaccination Disparities in Rural Adolescents (https://reporter.nih.gov/project-details/10887284) (K01); PI: Nadja Vielot; Organization: University of North Carolina – Chapel Hill; Grant Start Date: August 1, 2024; Aims to (1) collaborate with healthcare personnel in rural primary care clinics to measure appropriateness and acceptability of starting HPV (human papillomavirus) vaccination at age 9, allowing more time to achieve up-to-date coverage by age 13, and use findings to develop an intervention plan; (2) gauge acceptability of HPV vaccination starting at age 9 among family caregivers in rural areas and modify the intervention plan to maximize caregiver acceptability; and (3) pilot the intervention in four rural clinics, using electronic medical records to measure HPV vaccination coverage in a cohort of 9-year-old patients over 2 years.

#### Costs of Care

One study looked at the financial impacts of illness across patient subgroups.

The Cost of Illness: The Impact of COVID-19 on Patient Financial Outcomes (https://reporter.nih.gov/project-details/10903780) (K08); PI: Nora V. Becker; Organization: University of Michigan at Ann Arbor; Grant Start Date: September 1, 2022; Examines “financial toxicity,” or the financial consequences of illness. The grant first investigates which patient subgroups are at the highest risk of financial burden; then estimates the objective financial burden of a COVID-19 infection and assesses patients’ subjective financial distress related to their illness. The financial burden of a COVID-19 infection and patient financial distress is a topic that is integral to the delivery of primary care.

### Initiatives and Resources

In addition to annual updates to the National Healthcare Quality and Disparities Report described below, AHRQ shares a range of information and tools related to studying and addressing SDOHs (https://www.ahrq.gov/sdoh/index.html), including maintaining an SDOH database (https://www.ahrq.gov/sdoh/data-analytics/sdoh-data.html), which includes data through 2020 at the county, ZIP code, and census tract levels.

2023 National Healthcare Quality and Disparities Report

AHRQ has published this congressionally mandated report annually since 2003. The 2023 National Healthcare Quality and Disparities Report (https://www.ahrq.gov/research/findings/nhqrdr/nhqdr23/index.html) provides an overview of the quality of healthcare in the United States as well as information about disparities in care for specific groups.

This image shows the cover of a report entitled “2023 National Healthcare Quality and Disparities Report.”

Related materials include:

- A Chartbook on Patient Safety (https://www.ahrq.gov/research/findings/nhqrdr/chartbooks/patientsafety/index.html)
- A Data Spotlight: The Prevalence of Mental Health Conditions Was on the Rise Before the COVID-19 Pandemic and the Pandemic Had a Negative Effect on Mental Health (https://www.ahrq.gov/sites/default/files/wysiwyg/research/findings/nhqrdr/qdr-mental-health-data-spotlight.pdf)

## Behavioral Health and Substance Use Disorders

Behavioral health is an overarching term that includes treatment for “mental health and substance abuse conditions, life stressors and crises, stress-related physical symptoms, and health behaviors.”^(18)^ It is estimated that up to 70% of primary care visits are driven by behavioral health–related issues,^(19)^ and if untreated, these issues can exacerbate or cause physical health problems. Unfortunately, shortages of mental health professionals, particularly in rural areas; lack of insurance coverage for behavioral healthcare services; high out-of-pocket costs for care; and stigma can make it difficult for people to access the behavioral healthcare they need.^(20,21)^

Behavioral health integration is when medical and behavioral health clinicians work as a team to care for patients within a primary care setting.^(18)^ Evidence suggests that providing comprehensive behavioral healthcare within primary care settings leads to improved care and reduced costs.^(22)^ The American Medical Association reports that it is essential for primary care practices to accelerate behavioral health integration to help address unmet behavioral healthcare needs.^(23)^

In addition to funding primary care research grants to understand issues related to behavioral health and behavioral health integration, described below, AHRQ provides data to quantify behavioral health challenges and provides tools and resources to support clinicians with screening and treatment.

### Grants

Across AHRQ primary care research grants with active funding in FYs 2023 and 2024, 10 focus mainly on behavioral health and substance use disorders (SUDs). This includes five R18 grants (Research Demonstration and Dissemination Projects), two R01 grants (Research Projects), one R03 grant (Small Research Projects), one K01 grant (Research Career Programs), and one R36 award (Dissertation Grants).

One additional grant has some focus on behavioral health and is described in the Person-Centered Care section.

We summarize the 10 grants focused on behavioral health and SUDs below, organized by subtopic. The three subtopics are:

- Substance Use Disorders
- Behavioral Health Integration
- Behavioral Approach to Treating Chronic Pain

#### Substance Use Disorders

These five grants examine ways to treat or provide support for people with SUDs, including opioid use disorder (OUD). Four of the five grants were funded through a request for applications (RFA) called Supporting the Management of Substance Use Disorders in Primary Care and Other Ambulatory Settings (https://grants.nih.gov/grants/guide/rfa-files/RFA-HS-23-005.html).

[image] Connecting Primary Care to Substance Use Disorder Treatment Using a Telehealth Collaborative Care Platform (https://reporter.nih.gov/project-details/10932289) (R18); PI: Tyler S. Oesterle; Organization: Mayo Clinic Rochester; Grant Start Date: September 30, 2023; Develops an integrated behavioral health collaborative care platform using the Senyo Health app to deliver screening, brief intervention, and referral to treatment (SBIRT) for SUDs in primary care. This grant is part of the Supporting the Management of Substance Use Disorders in Primary Care and Other Ambulatory Settings (https://grants.nih.gov/grants/guide/rfa-files/RFA-HS-23-005.html) grant initiative.
Group Well Child Care Intervention for Infants of Mothers in Treatment for Opioid Use Disorder (https://reporter.nih.gov/project-details/10767333) (R18); PIs: Neera Goyal; Vanessa L. Short; Organization: Nemours Children’s Hospital, Delaware; Grant Start Date: April 1, 2020; Looks at the use of comprehensive group well-child visits for mothers with opioid use disorder and their children. The group visits examined in this study allow for increased time with the pediatrician, peer-to-peer learning, and an enhanced focus on behavior change and self-care.; Webinar icon Learn more about this study in a recent NCEPCR webinar: Qualitative Methods Used in AHRQ Funded Primary Care Research (https://www.ahrq.gov/ncepcr/about/pcr-webinar-series/qualitative-methods.html)
[image] Leveraging Social Determinants via Artificial Intelligence and Peer Coaching to Address Racial Disparities in Primary Care Among People Who Use Opioids (https://reporter.nih.gov/project-details/10931538) (R18); PIs: Babak Tofighi; Helen-Maria Lekas; Crystal Fuller Lewis; Organization: Friends Research Institute, Inc.; Grant Start Date: September 30, 2023; Examines the effectiveness of a previously developed artificial intelligence (AI)–driven texting tool to facilitate buprenorphine treatment through primary care for Black and Latino people who use opioids. The tool uses natural language processing to facilitate real-time text responses to patient queries (without requiring real-time staff engagement), combined with automated texts. The study conducts a three-arm, comparative effectiveness trial comparing text-based care coordination for people who use opioids along with AI-driven social determinants of health (SDOH)-enhanced text messaging (intervention arm-1) vs. AI-driven SDOH-enhanced text messaging only (intervention arm-2) vs. usual care including printed social services and clinical referrals (usual care arm). The research team also conducts a comprehensive economic evaluation to compare the relative economic value of each approach.; This grant is part of the Supporting the Management of Substance Use Disorders in Primary Care and Other Ambulatory Settings (https://grants.nih.gov/grants/guide/rfa-files/RFA-HS-23-005.html) grant initiative.
[image] Supporting Unhealthy Substance use care Through a whole person Approach and user centered INtegration into Primary Care (SUSTAIN) (https://reporter.nih.gov/project-details/10931543) (R18); PI: Sebastian Tong; Organization: University of Washington; Grant Start Date: September 30, 2023; Develops and tests a change package of interventions to treat unhealthy substance use. Participating primary care practices join a learning collaborative where they receive support to implement their selected intervention from the change package. The research team evaluates the practices’ implementation outcomes and conducts qualitative interviews to gather data on patient functioning, unhealthy substance use, recovery, process outcomes, and healthcare utilization.; This grant is part of the Supporting the Management of Substance Use Disorders in Primary Care and Other Ambulatory Settings (https://grants.nih.gov/grants/guide/rfa-files/RFA-HS-23-005.html) grant initiative.
[image] The STop UNhealthy Substance Use Now Trial (STUN II) (https://reporter.nih.gov/project-details/10928217) (R18); PI: Daniel E. Jonas; Organization: Ohio State University; Grant Start Date: September 30, 2023; Aims to improve screening for and management of substance use disorders in primary care. The trial tests whether practice facilitation can achieve rapid implementation of patient-centered outcomes research findings. It also tests whether learning collaboratives, performance incentives, or a combination of the two can significantly improve the implementation of screening for and management compared with practice facilitation alone.; This grant is part of the Supporting the Management of Substance Use Disorders in Primary Care and Other Ambulatory Settings (https://grants.nih.gov/grants/guide/rfa-files/RFA-HS-23-005.html) grant initiative.

#### Behavioral Health Integration

The four grants described below examine various approaches for integrating primary care and behavioral health.

[image] Building the Evidence for Adolescent Substance Use Preventive Care at Well-Visits from Mid-Adolescence to Young Adulthood Using the Longitudinal NEXT Study (https://reporter.nih.gov/project-details/10642111) (R03); PI: Arik V. Marcell; Organization: Johns Hopkins University; Grant Start Date: April 1, 2023; Aims to understand the benefits of preventive care about substance use for adolescents in primary care using the National Institutes of Health NEXT Study data. Specifically, the study seeks to understand the extent to which substance-using adolescents participate in well-visits, the proportion of adolescents who are asked and advised annually about substance use at well-visits, and the extent to which being asked and advised about substance use during adolescence is related to the prevention of future substance use initiation or reduction of substance use over time.
[image] Care Integration, Supportive Housing, and Outcomes for Medicaid Accountable Care Organization Enrollees with Behavioral Health Conditions (https://reporter.nih.gov/project-details/10896589) (R36); PI: Meagan J. Sabatino; Organization: University of Massachusetts Medical School – Worcester; Grant Start Date: August 1, 2024; Examines the impacts of integrated social and healthcare services on the experiences and outcomes of patients with behavioral health conditions in Massachusetts’ Medicaid program (MassHealth). The research team conducts qualitative interviews to identify barriers and facilitators to effective care delivery and understand patients’ experiences; conducts a cross-sectional analysis with survey and MassHealth administrative data to examine the relationship between primary care clinicians’ perceptions of clinical and social service integration and rates of acute and emergency healthcare utilization; and uses administrative data to quantify the effect of integrated housing supports on healthcare utilization among patients experiencing housing insecurity or homelessness.
[image] An Evidence-Based Leadership Training Intervention to Accelerate Integration of Behavioral Health and Primary Care (https://reporter.nih.gov/project-details/10886944) (K01); PI: Ann M. Nguyen; Organization: Rutgers Biomedical and Health Sciences; Grant Start Date: April 1, 2024; Develops and tests an evidence-based intervention to accelerate the implementation of integrated behavioral health in primary care by using leadership concepts to overcome organizational, attitudinal, and financial challenges. The study team identifies key implementation challenges as well as the leadership skills needed to successfully implement integrated behavioral health; develops an intervention based on the information collected; and then evaluates the preliminary effectiveness, feasibility, and acceptability of using the intervention in practice settings.
[image] Using Process Mapping to Optimize the Integration of Child Psychosocial Screenings in Primary Care, Promote Whole-Person Care, and Increase Family Linkages to Behavioral and Safety Net Services (https://reporter.nih.gov/project-details/11045981) (R01); PI: Monica Perez Jolles; Organization: University of Colorado – Denver; Grant Start Date: September 30, 2024; Evaluates the effectiveness of a system-level intervention designed to increase service referrals and follow-up to address the psychosocial needs of caregivers and children identified through primary care screenings (e.g., exposure to violence, racism, and insecure housing). The intervention being tested uses Process Service Mapping, a novel methodology that maps patients’ journeys to identify inequities, challenges, and action points to optimize service pathways.

#### Behavioral Approach to Treating Chronic Pain

One grant looked at a novel behavioral health approach for treating chronic pain.

Impact of a Novel Community-Based Biobehavioral Chronic Pain Team Training Program (4PCP) on Practitioner and Patient Outcomes (https://reporter.nih.gov/project-details/10928120) (R01); PI: Thomas C. Chelimsky; Organization: Virginia Commonwealth University; Grant Start Date: September 30, 2022; Looks at using a “biobehavioral” approach to treating chronic pain rather than a “biopharmacologic” approach. The biobehavioral approach treats chronic pain syndrome as a brain disorder that has been reinforced through negative cognitive, emotional, and behavioral habits. In a previous pilot study, the researchers demonstrated that primary care practitioners were eager to implement this new approach, and those who did so had increased confidence with chronic pain management, reduced visit times, and improved patient pain. The primary care practices in this study receive training from a paired psychologist and a physical therapist to build a clinical team. The study examines whether patient improvements can be sustained for 2 years and whether increased practitioner confidence leads to a tapering of prescribed opioids.

### Initiatives and Resources

AHRQ continues to host The Academy for Integrating Behavioral Health & Primary Care (https://integrationacademy.ahrq.gov/), which has several materials from 2023 and 2024, described below. There are also a number of other recent AHRQ materials related to behavioral health and SUDs, including a change package to improve information and care for older adults related to opioid use and misuse and treating OUD and a webinar presenting AHRQ-funded research focused on behavioral health integration in primary care.

Compendium of Resources for Managing Unhealthy Alcohol Use

This image shows the cover of a report entitled “Environmental Scan Final Report Managing Unhealthy Alcohol Use in Primary Care.”

This report (https://integrationacademy.ahrq.gov/sites/default/files/2023-08/unhealthy-alcohol-use-environmental-scan-report.pdf?_gl=1*1lmthhl*_ga*MTgyMTYyMzk1OC4xNzM5MjE1NzA2*_ga_1NPT56LE7J*MTc0MzQzOTU2OC41Ny4xLjE3NDM0Mzk2MDQuMC4wLjA.) from the technical assistance and evaluation center for EvidenceNOW: Managing Unhealthy Alcohol Use includes a compendium (Appendix III) of nearly 600 tools and resources for diagnosing and treating unhealthy alcohol use from The Academy for Integrating Behavioral Health and Primary Care’s searchable database (https://integrationacademy.ahrq.gov/products/substance-use-resources/environmental-scan/unhealthy-alcohol-use?_gl=1*7ld060*_ga*MTgyMTYyMzk1OC4xNzM5MjE1NzA2*_ga_1NPT56LE7J*MTc0MzQzOTU2OC41Ny4xLjE3NDM0Mzk2MjQuMC4wLjA.).

Pharmacotherapy for Adults with Alcohol Use Disorder in Outpatient Settings: Systematic Review

This evidence report (https://effectivehealthcare.ahrq.gov/products/alcohol-use-disorders/research?) from the Effective Healthcare Program updates a report on pharmacotherapy for treating alcohol use disorder.

Opioid Use in Older Adults: Compendium of Resources

This change package (https://www.ahrq.gov/opioids/implementing-what-works/compendium-intro.html) is designed to help primary care practices and healthcare systems improve opioid medication management and prevent opioid misuse and opioid use disorder in older adults. The change package includes:

- An interactive compendium (https://www.ahrq.gov/opioids/implementing-what-works/compendium.html) that links to recommended activities and tools and resources, organized by seven key areas in which change may be needed, called high-leverage changes and change strategies.
- A self-assessment that can be used by practices to determine which of the high-leverage changes are their highest priority and which they have the capacity to address. Self-assessment materials include:
  - Practice Self-Assessment Tool for Opioid Use in Older Adults (https://www.ahrq.gov/sites/default/files/wysiwyg/opioids/compendium/opioids-compendium-self-assessment.pdf)
  - How to Complete the Practice Self-Assessment Tool (https://www.ahrq.gov/sites/default/files/wysiwyg/opioids/compendium/opioids-compendium-self-assessment-instructions.pdf)
- Five case studies describing how primary care practices implemented a quality improvement project using tools from the compendium and their lessons learned:
  - Using an Electronic Health Record System to Prevent Opioid Use Disorder in Older Adults in Primary Care Practices Case Study (https://www.ahrq.gov/sites/default/files/wysiwyg/opioids/compendium/opioids-case-study-ehr-oud.pdf)
  - Creating a Work-Around to Implement Fall Risk Screening for Older Adults Using Appointment Notes Case Study (https://www.ahrq.gov/sites/default/files/wysiwyg/opioids/compendium/opioids-case-study-work-around.pdf)
  - Implementing Opioid Risk Screening for Older Adults Using Automated Patient Reminders in an Electronic Health Record Case Study (https://www.ahrq.gov/sites/default/files/wysiwyg/opioids/compendium/opioids-case-study-risk-screening.pdf)
  - New Clinical Processes and Improving Workflows for Opioid Management in a Geriatric Clinic: Using Input from The Team Case Study (https://www.ahrq.gov/sites/default/files/wysiwyg/opioids/compendium/opioids-case-study-clinical-processes-workflows.pdf)
  - Supporting Clinical Staff Who Prescribe Opioids to Older Adults: Providing Targeted Educational Sessions to Meet Needs Case Study (https://www.ahrq.gov/sites/default/files/wysiwyg/opioids/compendium/opioids-case-study-prescribe-opioids.pdf)

NCEPCR Webinar: Research on the Integration of Behavioral Health in Primary Care

This image shows a screenshot from the NCEPCR webinar entitled “Research on Integration of Behavioral Health in Primary Care.”

NCEPCR hosted a webinar (https://www.ahrq.gov/ncepcr/about/pcr-webinar-series/behavioral-health.html) in March 2024 to highlight research focused on the integration of behavioral health in primary care. The webinar included two AHRQ grantees who presented on their work researching behavioral health tools and interventions in ambulatory care settings. In addition, the webinar included a presentation on The Academy for Integrating Behavioral Health and Primary Care, AHRQ’s national resource for integrating behavioral health and primary care.

This image shows the logo of The Academy for Academy for Integrating Behavioral Health and Primary Care.

The Academy for Integrating Behavioral Health and Primary Care (https://integrationacademy.ahrq.gov/news-and-events/news/eating-disorder-resources-clinicians-and-patients) website serves as a centralized portal for sharing information and materials on behavioral health integration. The portal includes several primary care-relevant materials released in 2023 and 2024, including the following Topic Briefs:

- Integrating Harm Reduction into Primary Care Practices (https://integrationacademy.ahrq.gov/news-and-events/news/integrating-harm-reduction-primary-care-practices?_gl=1*1m920cz*_ga*MTA5OTUxMzQwMS4xNzI3OTc3NzYw*_ga_1NPT56LE7J*MTczNTg0NjI2MS4zOS4xLjE3MzU4NDc4NTkuMC4wLjA.)
- How Community Engagement Can Support Whole-Person Primary Care (https://integrationacademy.ahrq.gov/products/topic-briefs/community-engagement-for-whole-person-care)
- The Role of Behavioral-Developmental Health Screening and Response for Children Ages 0-5 in Pediatric Primary Care (https://integrationacademy.ahrq.gov/products/topic-briefs/age-0-5-behavioral-development)
- The Role of Low-Threshold Treatment for Patients with OUD in Primary Care (https://integrationacademy.ahrq.gov/products/topic-briefs/oud-low-threshold-treatment)
- Potential Usefulness of Apps and Other Digital Technologies for Improving Access to Behavioral Health in Primary Care (https://integrationacademy.ahrq.gov/products/topic-briefs/behavioral-health-apps)

This is a photo of primary care researcher, Julie Salvador.

In a previous AHRQ primary care research grant led by PI Julie Salvador, a research team applied the Project ECHO^©^ model to train rural primary care clinicians in New Mexico to provide evidence-based care for patients with opioid use disorder. This has led to increased access to medications for opioid use disorder (MOUD) in this largely rural state, as more primary care clinicians are getting trained in providing MOUD and offering it to their patients. The regularly held virtual training program is now open to clinicians across the United States. To learn more about this study and how you can access the training program read the NCEPCR Impact Story: Increasing Access to Treatment for Opioid Use Disorder in Rural Communities Through a Virtual Clinician Training and Support Program (https://www.ahrq.gov/sites/default/files/wysiwyg/ncepcr/about/impact-stories/increasing-access.pdf).

## Digital Healthcare

Digital healthcare is the use of health information technology to collect and share health information to improve the efficiency, quality, and accessibility of care. Digital healthcare approaches have grown exponentially in recent years such that they are now a ubiquitous and essential part of care.^(24)^

Digital healthcare encompasses a variety of technologies and approaches, including:

- Electronic health records (EHR) or electronic medical records (EMR) along with patient portals are used to securely track, share, and review health information across a practice or health system and provide clinical decision support.
- Telehealth or telemedicine includes the use of phone calls, video conferences, or other online tools to host virtual consultations between patients and clinicians.
- Mobile health (mHealth) and electronic health (eHealth) refers to the use of smart phones or wearable devices to collect patient-generated health data for the purpose of remote health monitoring and data collection, or to provide care reminders and health education.
- Artificial Intelligence (AI) uses algorithms and machine learning to support patient care, such as to aid diagnosis and to support shared decision making.

The use of digital healthcare in primary care has the promise of increasing access to care, especially for patients living in rural or other limited-access areas; enhancing care coordination across healthcare settings; supporting clinical decision making; reducing clinician burden; and enhancing patient engagement through electronic self-management tools. However, digital healthcare has also been linked to increased clinician burnout, introduces problems with lack of interoperability across systems, can increase barriers for patients without adequate access to technology, and can lead to moving a clinician’s focus from the patient in front of them to a computer screen.^(24)^ Research is needed to understand how to best realize the potential of digital healthcare while minimizing the risks.

AHRQ’s authorizing legislation requires the agency to promote healthcare quality improvement through research on “existing and innovative technologies.”^(14)^ AHRQ’s Division of Digital Healthcare Research produces and disseminates evidence on how digital healthcare can improve the quality, safety, and effectiveness of healthcare while also improving patient experiences.^(25)^ This section of the report includes a summary of AHRQ’s digital healthcare grants, initiatives, and resources with a focus on primary care.

### Grants

Across AHRQ primary care research grants with active funding in FYs 2023 and 2024, 10 focus mainly on digital healthcare. This includes five R01 grants (Research Projects), two R18 grants (Research Demonstration and Dissemination Projects), two R21 grants (Exploratory/Developmental Grants), and one R03 grant (Small Research Project).

An additional 27 grants include some focus on digital healthcare and are described in other topic area sections, including 10 in Patient Safety, five in Practice and Quality Improvement, four in Person-Centered Care, three in Primary Care Workforce, two in Behavioral Health and Substance Use Disorders, one in Healthcare Systems and Infrastructure, one in Health Disparities, and one in Public Health and Community Integration.

We summarize the 10 grants focused on digital healthcare below, organized by subtopic. Subtopics are:

- mHealth/eHealth
- Telehealth/Telemedicine
- Clinical Decision Support Tools
- Other EHR Tools

#### mHealth and eHealth

Four grants examine various approaches to providing care and monitoring through mobile devices and other electronic approaches.

Care Transitions App for Patients with Multiple Chronic Conditions (https://reporter.nih.gov/project-details/10894704) (R01); PIs: Lipika Samal; Patricia C. Dykes; Organization: Brigham and Women’s Hospital; Grant Start Date: September 30, 2022; Develops and tests the effectiveness of an app to support care transitions between the hospital, home, and primary care clinic to reduce adverse events post-discharge from the hospital. The app contains a digital post-discharge transitional care plan, modules for multiple chronic conditions, relevant lab values, education specific to the patient’s prescribed medications, and a functionality that allows patients to ask questions to support their recovery goals.
Impact and Sustainability of a Digitally-Based Diabetes Prevention Program (https://reporter.nih.gov/project-details/10893461) (R01); PI: Yoshimi Fukuoka; Organization: University of California, San Francisco; Grant Start Date: August 1, 2021; Assesses the effectiveness and sustainability of a digitally-based diabetes prevention program for reducing body weight and HbA1c in adults with prediabetes and obesity through a randomized controlled trial. The findings from this study have clear implications for primary care, where diabetes prevention is a common part of care.
[image] A Novel Patient-Facing Mobile Platform to Collect and Implement Patient-Reported Outcomes and Voice Biomarkers in Underserved Adult Patients with Asthma (https://reporter.nih.gov/project-details/10813037) (R21); PIs: Jonathan M. Feldman; Sunit Jariwala; Organization: Albert Einstein College of Medicine; Grant Start Date: April 1, 2023; Enhances the ASTHMAXcel PRO mobile app for patients with asthma by adding a respiratory symptoms risk score based on vocal biomarker technology (ASTHMAXcel Voice), which facilitates shared decision making and social determinants of health screening and referrals and enables self-management and remote care coordination. ASTHMAXcel Voice is adjusted based on stakeholder feedback and implemented in an outpatient setting (including primary care and specialty care), where measurements such as asthma control, emergency department visits, and patient/clinician satisfaction are collected.; Webinar icon Learn more about this study in a recent Digital Healthcare Research webinar: Digital Healthcare Innovations to Engage and Empower Patients in Their Care (https://digital.ahrq.gov/national-webinars/digital-healthcare-innovations-engage-and-empower-patients-their-care)
Using Smart Devices to Implement an Evidence-Based eHealth System for Older Adults (https://reporter.nih.gov/project-details/10893332) (R18); PIs: David H. Gustafson; Marie-Louise Mares; Organization: University of Wisconsin – Madison; Grant Start Date: August 1, 2020; Implements a smart-system (a smart speaker plus visual display) version of an existing Elder Tree intervention – a program that supports the self-management of health for older adults with multiple chronic conditions who live independently and whose care is managed by primary care clinicians. This grant tests a smart-system version compared with the computer-based system on outcomes, including quality of life, hospital readmission, and medication adherence.; Webinar icon Learn more about this study in a recent Digital Healthcare Research webinar: Digital Healthcare Innovations to Engage and Empower Patients in Their Care (https://digital.ahrq.gov/national-webinars/digital-healthcare-innovations-engage-and-empower-patients-their-care)

#### Telehealth/Telemedicine

Three grants focus on use of telehealth or telemedicine. See the section in Telehealth/Telemedicine in Appendix B for more grants and information about this topic.

Implementing Telemedicine to Improve Appropriate Antibiotic Prescribing for Acute Respiratory Tract Infections (https://reporter.nih.gov/project-details/10840279) (R01); PIs: Tamar Barlam; Mari-Lynn Drainoni; Organization: Boston Medical Center; Grant Start Date: June 1, 2022; Examines whether telehealth visits can be used to improve the management of acute respiratory tract infections, including reducing inappropriate prescribing of antibiotics in ambulatory care settings including primary care.
[image] The Role of Telehealth in Improving Access to and Costs of Unscheduled Care Among Lower-Income Individuals (https://reporter.nih.gov/project-details/10932315) (R01); PI: Lindsay Allen; Organization: Northwestern University at Chicago; Grant Start Date: September 30, 2023; Aims to measure the impact of different telehealth delivery models on cost, downstream care (e.g., primary care) and immediate access to care among low-income individuals to provide Medicaid agencies and policymakers with information needed to decide whether to permanently extend COVID-era telehealth policies.
Badge icon [image] Telemedicine Preparation for Older Adults with Type 2 Diabetes (https://reporter.nih.gov/project-details/10785410) (R03); PIs: Goutham Rao; Kelsey Ufholz; Organization: University Hospitals of Cleveland; Grant Start Date: September 1, 2023; Aims to develop a digital skills training intervention to prepare older, mostly African American adults with Type II diabetes to participate in and benefit from telemedicine appointments for primary care. Feedback is collected from patients who complete the training about their satisfaction with it and whether it helped them during their telemedicine appointment (if applicable).

#### Clinical Decision Support Tools

Two grants create or expand existing clinical decision support tools.

[image] An AI-Directed CDS Tool to Reduce Iron Deficiency Anemia in Pregnancy: A Randomized Controlled Trial (AID-IDA Trial) (https://reporter.nih.gov/project-details/10951600) (R21); PI: Mark Allen Clapp; Organization: Massachusetts General Hospital; Grant Start Date: August 1, 2024; Builds a clinical decision support tool to identify iron deficiency and anemia in pregnancy and prevent postpartum hemorrhage. The tool comprises an iron deficiency screening and management predictive model for individuals at high risk for postpartum hemorrhage. Tool includes prompts for clinicians to screen and treat identified patients during routine obstetric care. Conducts a randomized controlled trial to determine the tool’s efficacy.
Engaging Patients to Enable Interoperable Lung Cancer Decision Support at Scale (https://reporter.nih.gov/project-details/10890591) (R18); PI: Kensaku Kawamoto; Organization: University of Utah; Grant Start Date: August 1, 2022; Expands an existing clinical decision support program (Decision Precision+) designed to analyze electronic health record data to prompt doctors to discuss lung cancer screening with eligible patients with individually tailored information on the benefits and harms of screening. Adapts Decision Precision+ to integrate with a patient portal (MyLungHealth) that patients use directly to learn about lung cancer screening. Tests how healthcare systems implement MyLungHealth in primary care practices and examines the additional benefit of MyLungHealth for practices that already use Decision Precision+.; Webinar icon Learn more about this study in a recent Digital Healthcare Research webinar: Transforming Guidelines into Action: Clinical Decision Support at the Point of Care (https://digital.ahrq.gov/national-webinars/transforming-guidelines-action-clinical-decision-support-point-care)

#### Other EHR Tools

This grant evaluated EHR tools that were not a clinical decision support tool.

[image] Assessing the Effects of EHR Optimization Interventions in Primary Care (https://reporter.nih.gov/project-details/10978784) (R01); PIs: David W. Bates; Lisa Rotenstein; Organization: Brigham and Women’s Hospital; Grant Start Date: August 1, 2024; Evaluates the impact of three interventions for EHR optimization in primary care settings to better understand the pros and cons of each intervention in the context of the primary care clinician’s work experience. Using data from 210 practice sites, interviews with clinicians, and estimating the costs of implementing each intervention, the study hopes to gather insights about how to improve clinicians’ experiences working with EHRs and the quality of care provided.

### Initiatives and Resources

AHRQ’s Digital Healthcare Research Program’s webpages (https://digital.ahrq.gov/) include many reports, tools and resources, and information about funding opportunities that may be of interest to primary care researchers. This includes an article from the Journal of the American Informatics Association (“AHRQ’s Digital Healthcare Research Program: 20 Years of Advancing Innovation and Discovery (https://academic.oup.com/jamia/article/31/11/2766/7796609)”) and the report Improving Healthcare Through AHRQ’s Digital Healthcare Research Program: 2023 Year in Review (https://digital.ahrq.gov/program-overview/research-reports/2023-year-review).

No new primary care–related digital healthcare initiatives or resources were released by AHRQ in 2023 and 2024.

## Person-Centered Care

The National Academies of Sciences, Engineering, and Medicine (NASEM) defines high-quality primary care as “continuous, person-centered, relationship-based care.”^(17)^ Person-centered care is based on the patient’s unique needs, preferences, and values,^(26)^ and focuses on the individual within the broader context of their community, family, and life experience. This type of comprehensive, whole-person care requires clinicians to actively involve patients and their families as partners in clinical decision making and to recognize the value of patient self-management – particularly for those with chronic conditions. Providing person-centered care is based on improved communication and trust between clinicians and patients and can lead to improved patient outcomes, increased patient and clinician satisfaction, and even decreased healthcare costs.^(27)^ In addition, the inclusion of patients and families as partners in primary care research is important for identifying which health outcomes and research questions are most relevant and responsive to the needs of those receiving the care.

This section includes grants, initiatives, and resources with a focus on person-centered care in primary care settings.

### Grants

Across AHRQ primary care research grants with active funding in FYs 2023 and 2024, ten focus mainly on person-centered care. This included six R01 grants (Research Projects), two R18 grants (Research Demonstration and Dissemination Projects), and two R21 grants (Exploratory/Development Grants).

An additional 13 grants include some focus on person-centered care and are described in other topic area sections, including four in Health Disparities, three in Practice and Quality Improvement, two in Patient Safety, two in Digital Healthcare, one in Healthcare Systems and Infrastructure, and one in Behavioral Health and Substance Use Disorders.

We summarize the ten grants focused on person-centered care below, organized by subtopic. The subtopics are:

- Patient-Facing Tools for Health Management and Decision Support
- Approaches to Increase Patient-Centered Care
- Family Decision Making in Telehealth

#### Patient-Facing Tools for Health Management and Decision Support

Six studies focused on developing, improving, measuring, or evaluating tools to help patients manage and make decisions about their care.

Development of a Shared Decision-Making Support (SDM-S) Measure for Use with Team-Based Care (https://reporter.nih.gov/project-details/10692620) (R01); PI: Jennifer M. Elston Lafata; Organization: University of North Carolina – Chapel Hill; Grant Start Date: September 1, 2021; Develops valid patient-reported shared decision-making support (SDM-S) measures that incorporate four distinct SDM phases: choice awareness, consideration of alternatives/preferences, choice-making, and choice implementation. Tests the measures in four contexts (lung cancer screening, colorectal cancer screening, rectal cancer treatment, and prostate cancer treatment) to evaluate performance and acceptability among primary care and oncology patients.
iMatter2: An AI-Driven Approach to Supercharge a Novel Digital Patient-Reported Outcomes Tool for Diabetes Management (https://reporter.nih.gov/project-details/10876986) (R01); PIs: Antoinette M. Schoenthaler; Devin M. Mann; Organization: New York University School of Medicine; Grant Start Date: July 1, 2023; Builds on an existing evaluation of an innovative mobile health patient-reported-outcomes tool for managing type 2 diabetes (iMatter). Uses a theory-driven and user-centered design approach across two phases: (1) a formative phase using a mixed-methods approach to enhance and user-test iMatter2 in primary care practices serving minority populations; and (2) a clinical trial phase, to test the effectiveness of iMatter2 verses usual care on HbA1c reduction at 12 months among 353 patients with uncontrolled type 2 diabetes.; Webinar icon Learn more about this study in a recent Digital Healthcare Research webinar: Empowering Patients to Change Behavior Using Digital Healthcare Tools (https://digital.ahrq.gov/national-webinars/empowering-patients-change-behavior-using-digital-healthcare-tools)
[image] LabGenie: A Patient-Engagement Tool to Aid Older Adults’ Understanding of Lab Test Results (https://reporter.nih.gov/project-details/10869316) (R21); PIs: Zhe He; Mia Liza A. Lustria; Organization: Florida State University; Grant Start Date: April 1, 2024; Develops and evaluates LabGenie: a web-based patient engagement tool to help patients understand and act upon their lab results. LabGenie is particularly geared towards older adults, who face unique barriers to patient portals including low health literacy and technology skills. The project examines the potential impact of Lab Genie on clinical workflow and burden in primary care settings.; Magnifying glass icon Learn more about this study in a Primary Care Research Profile: An AI-Powered Tool to Support Older Adults in Understanding Lab Test Results (LabGenie) (https://www.ahrq.gov/sites/default/files/wysiwyg/ncepcr/about/profiles/profile_he.pdf)
Patient-Centered Diabetes Education as an Integral Part of an Electronic Clinic Note Using the SEE-Diabetes Modules (https://reporter.nih.gov/project-details/10598095) (R21); PI: Min Soon Kim; Organization: University of Missouri – Columbia; Grant Start Date: April 1, 2022; Develops an educational decision aid that enables older adults with diabetes to choose a strategy for diabetes self-management education and support that has the best potential to achieve clinical and health benefits for them. Refines and tests the decision aid for feasibility in primary care and diabetes specialty care settings and for preliminary outcomes.
Patient Perspectives on Prescription Opioid Discontinuation: Understanding and Promoting Safe Transitions (https://reporter.nih.gov/project-details/10809643) (R01); PI: Clarisa Wen-Ling Hsu; Organization: Kaiser Foundation Research Institute; Grant Start Date: June 1, 2022; Investigates the experiences of patients and primary care clinicians who have discontinued long-term opioid therapy (LTOT). Develops a patient-centered decision aid to improve patient-provider communication around discontinuation of LTOT and pilot tests the decision aid with patients.
Badge icon SDMo – a Measure of the Occurrence of SDM in the Care of Patients with Chronic Conditions (https://reporter.nih.gov/search/6bpyl_KUQUqyBG8urALrIA/project-details/10928714) (R01); PI: Ian Hargraves; Organization: Mayo Clinic Rochester; Grant Start Date: September 30, 2022; Develops a measure of shared decision making (SDM) occurrence and estimates the measure’s reliability and validity. This new measure of SDM occurrence can help uncover how frequently SDM techniques are used in the care of patients with chronic conditions in primary care or other settings, and test associations between SDM and behavioral and physical health outcomes.

#### Approaches to Increase Patient-Centered Care

Three studies reviewed different approaches to increase patient-centered care.

Enhanced Care Planning and Clinical-Community Linkages to Comprehensively Address the Basic Needs of Patients with Multiple Chronic Conditions (https://reporter.nih.gov/project-details/10548165) (R01); PI: Alexander H. Krist; Organization: Virginia Commonwealth University; Grant Start Date: March 5, 2019; Implements and tests an enhanced care planning program to help patients manage multiple chronic conditions. Includes the use of an enhanced care planning tool in primary care to screen patients for health behavior, mental health, and social needs. Working with a navigator, patients help prioritize their needs, create a care plan, and write a narrative to guide care; and then connects patients to needed resources in the community. Implemented a clinician-level randomized controlled trial to study how primary care clinicians participate in models for connecting patients to needed community services, and measures whether it improves their health outcomes.; Webinar icon Learn more about this study in a recent NCEPCR webinar: Research on Person-Centered Care (https://www.ahrq.gov/ncepcr/about/pcr-webinar-series/person-centered-care.html).
Ready and Healthy for Kindergarten: A Primary Care Innovation to Promote a 360-Degree View of Child Health (https://reporter.nih.gov/project-details/10928263) (R18); PI: Manuel E. Jimenez; Organization: Rutgers Biomedical and Health Sciences; Grant Start Date: September 30, 2021; Tests an online family wellness program that uses anticipatory guidance on health topics important to school readiness (e.g., nutrition and physical activity) to introduce language and literacy skills to Latino dual language learners from families with a low income. Conducts a developmental evaluation to refine and optimize the program for implementation in primary care. Then, conducts a randomized control trial to test the effects of the program on child and parent outcomes, and a process evaluation to explore reach, implementation, and user experience.
Scaling Interoperable Clinical Decision Support for Patient-Centered Chronic Pain Care (https://reporter.nih.gov/project-details/10689772) (R18); PIs: Ramzi George Salloum; Christopher Albert Harle; Organization: University of Florida; Grant Start Date: September 13, 2021; Develops and tests a clinical decision support tool to help primary care clinicians work with their patients to choose a pain treatment approach that best balances the potential risks and benefits for the individual patient. This tool helps to avoid inappropriate discontinuation of opioids for the patients for whom the benefits of opioids outweigh the risks.

#### Family Decision Making in Telehealth

One study compared engagement in family decision making in telehealth versus in-person primary care for children with chronic conditions.

Comparing Family Decision Making Engagement in Telehealth Versus In-Person Primary Care for Children with Chronic Conditions (https://reporter.nih.gov/project-details/10929350) (R01); PI: Ellen A. Lipstein; Organization: Cincinnati Children’s Hospital Medical Center; Grant Start Date: September 30, 2022; Aims to compare the telehealth and in-person decision-making processes and outcomes in pediatric primary care for children with chronic conditions. Uses a combination of family surveys, video recordings of healthcare visits, and qualitative interviews to understand experiences of decision-making during telehealth and in-person visits.; Webinar icon Learn more about this study in a NCEPCR webinar: Qualitative Methods Used in AHRQ-Funded Primary Care Research. (https://www.ahrq.gov/ncepcr/about/pcr-webinar-series/qualitative-methods.html)

### Initiatives and Resources

In 2023 and 2024, AHRQ released the updated Health Literacy Universal Precautions Toolkit and added an outpatient mental health survey to the Consumer Assessment of Healthcare Providers and Systems (CAHPS^®^) surveys. AHRQ’s materials on person-centered Care from FYs 2023 and 2024 that are primary care-relevant are described below.

Person-Centered Preventive Healthcare: Gathering Stakeholder Input on Evidence and Implementation

AHRQ convened a 25-member technical expert panel multiple times to advise on identifying high-quality clinical preventive services (such as vaccinations and screening tests) and delivering these services in ways that are person centered.

This project (https://www.ahrq.gov/sites/default/files/wysiwyg/ncepcr/research/pcph-stakeholder-report.pdf) resulted in a series of reports:

- Prioritizing Clinical Preventive Services (https://www.ahrq.gov/sites/default/files/wysiwyg/ncepcr/research/prioritizing-clinical-preventive-services-full.pdf) (and an Executive Summary (https://www.ahrq.gov/sites/default/files/wysiwyg/ncepcr/research/person-centered-prevent-care-summary.pdf))
- Gathering Stakeholder Input on Evidence and Implementation (https://www.ahrq.gov/sites/default/files/wysiwyg/ncepcr/research/gathering-stakeholder-input-full.pdf) (and an Executive Summary (https://www.ahrq.gov/sites/default/files/wysiwyg/ncepcr/research/gathering-stakeholder-input-summary.pdf))
- Reaching Adolescents to Deliver Preventive Services (https://www.ahrq.gov/sites/default/files/wysiwyg/ncepcr/research/reaching-adolescents-full.pdf)
- Engaging in Challenging Conversations About Screening (https://www.ahrq.gov/sites/default/files/wysiwyg/ncepcr/research/engaging-challenging-full.pdf)

Health Literacy Universal Precautions Toolkit

This image shows the cover page of a report entitled “Health Literacy Universal Precautions Toolkit.”

AHRQ’s Health Literacy Universal Precautions Toolkit (https://www.ahrq.gov/health-literacy/improve/precautions/index.html) was updated to the third edition in 2024. The toolkit provides evidence-based guidance for clinicians about how they can help ensure their patients understand, and can act on, important health information and includes tools with concrete action items to support busy clinicians.

This image shows the logo of Consumer Assessment of Healthcare Providers and Systems (CAHPS).

AHRQ’s Consumer Assessment of Healthcare Providers and Systems (CAHPS^®^) surveys (https://www.ahrq.gov/cahps/about-cahps/index.html) help to build an understanding of patients’ experience with healthcare to help ensure that care is safe and centered on patients’ needs.

There are several CAHPS^®^ surveys focused on different areas of care. In 2024, the CAHPS added an outpatient mental health survey (https://www.ahrq.gov/cahps/surveys-guidance/mental-health/index.html). This survey asks adult patients to provide feedback on their experiences with mental health and substance use disorder services received in any outpatient setting, including primary care. In addition to other groups, clinicians and medical groups can use the results from this survey to identify strengths and weaknesses in service provision and delivery from the patient’s perspective.

NCEPCR Webinar: Research on Person-Centered Care

This image shows a screenshot from the NCEPCR webinar entitled “Research on Person-Centered Care.”

NCEPCR hosted a webinar (https://www.ahrq.gov/ncepcr/about/pcr-webinar-series/person-centered-care.html) in June 2024 focused on personcentered research techniques, models, tools, and programs and their impact on patient health outcomes. Three AHRQ grantees presented their research about the associations between shared decision making and chronic care; how primary care clinicians participate in models for connecting patients to community services; and implementation of a scalable, person-centered chronic pain management program.

This is a photo of primary care researcher, Leslie Lenert.

In a previous AHRQ primary care research grant led by PIs Leslie Lenert (pictured) and Alyssa Rheingold, the research team developed and demonstrated the value of an electronic health record –based tool to improve confidential screening and risk management for intimate partner violence in primary care settings.

To learn more about this study and how to access this publicly available tool read the NCEPCR Impact Story: A Better Approach for Screening Women for Intimate Partner Violence in Primary Care (https://www.ahrq.gov/sites/default/files/wysiwyg/ncepcr/about/impact-stories/better-approach.pdf)

## Primary Care Workforce

A robust and stable primary care workforce is required to ensure access to high-quality primary care across communities in the United States, as recommended by the National Academies of Sciences, Engineering, and Medicine (NASEM).^(17)^ Unfortunately, the country continues to face a concerning shortage of primary care physicians and poor distribution of primary care clinicians – including physicians, nurse practitioners (NPs), and physician assistants (PAs). The proportion of healthcare trainees who choose to focus on primary care has decreased in recent years, and primary care training now disproportionally takes place in hospitals rather than in the community settings where primary care services mainly occur.^(17,28)^ In fact, the U.S. primary care physician workforce is shrinking, with a projected shortage unable to meet patient demand by 2035.^(17,29)^ In addition, there are growing gaps in access to care in medically underserved communities – such as rural areas – due to wide variation in where primary care clinicians are located.^(17)^

Although it has eased since the COVID-19 public health emergency, the primary care workforce continues to face concerningly high rates of burnout.^(30,31)^ In addition to the personal toll on physicians and their families, burnout has been found to lead to poorer quality of care, lower patient satisfaction, and decreased patient safety.^(32–34)^ Poor physician well-being, low professional satisfaction, and high burnout leads some clinicians to reduce their hours or leave practice altogether, further exacerbating workforce shortages.^(33)^

Ongoing research is needed to better understand how to measure, expand, and strengthen the primary care workforce, mitigate clinician burnout, leverage innovative technologies to reduce burden, and examine how to best support primary care clinicians in communities throughout the United States. Studies that measure, track, and contribute to understanding the experience of the primary care workforce are necessary to ensure access to quality primary care. AHRQ has identified primary care workforce as a topic area of interest, although investments in 2023 and 2024 were limited to a small number of grants, as described in this section.

### Grants

Across AHRQ primary care research grants with active funding in FYs 2023 and 2024, six focus mainly on primary care workforce. This includes three R03 grants (Small Research Projects), one R01 grant (Research Project), one R36 award (Dissertation Grant), and one K08 grant (Mentored Clinical Scientist Development Award).

An additional 10 grants include some focus on primary care workforce and are described in other topic area sections, including four in Healthcare Systems and Infrastructure, two in Behavioral Health and Substance Use Disorders, one in Digital Healthcare, one in Healthcare Disparities, one in Patient Safety and one in Practice and Quality Improvement.

We summarize the six grants focused on primary care workforce below, organized by subtopic. The subtopics are:

- Clinician and Staff Burnout
- The Role of the NP in Primary Care
- Using AI for Documentation

#### Clinician and Staff Burnout

Three studies examine how to identify and address burnout and burden in the primary care workforce.

Development and Validation of a Prediction Model to Address Physician Burnout (https://reporter.nih.gov/project-details/10914807) (K08); PI: Daniel Tawfik; Organization: Stanford University; Grant Start Date: September 30, 2020; Develops and validates a tool to identify the primary care practices at greatest risk for clinician burnout. The tool uses an algorithm that collates EHR data, metadata, and progress notes to produce predicted practice burnout scores to facilitate the prevention of burnout before it occurs.; Learn more about this study in the NCEPCR Impact Story: Enabling Real-Time Identification of Burnout Risk Among Clinicians in Primary Care Practices (https://www.ahrq.gov/sites/default/files/wysiwyg/ncepcr/about/impact-stories/enabling-real-time.pdf)
Badge icon [image] Organizational Strategies to Support Community Health Center Well-Being (https://reporter.nih.gov/project-details/11054324) (R03); PI: Natalie Virginia Schwatka; Organization: University of Colorado – Denver; Grant Start Date: September 1, 2024; Evaluates the safety, health, and well-being needs of the workforce at federally qualified health centers (FQHCs), with the goal of reducing burnout and improving retention. Aims to determine how FQHCs can use leadership practices to improve the working environment at FQHCs for existing and future staff. Assesses the relationship between FQHC primary care workforce well-being and turnover.
[image] Understanding and Addressing Community Health Center Burden, Resiliency, and Burnout – Systems Engineering Analyses and Approaches (https://reporter.nih.gov/project-details/11029672) (R01); PI: James C Benneyan; Organization: Northeastern University; Grant Start Date: September 30, 2024; Uses systems science and systems engineering approaches to better understand and address the impacts of growing asynchronous care demands (e.g., patient portals, EHR email, and text messaging) on clinician burnout. Uses analytic process simulation and system dynamics models to better understand the issues and system resiliency analysis and design methods to suggest more robust adaptive processes.

#### The Role of the NP in Primary Care

Two studies focus on the role of the NP in the primary care workforce.

[image] The Impact of Nurse Practitioner Work Environment and Community Characteristics on Acute Care Utilization by Older Adults with Multiple Chronic Conditions (https://reporter.nih.gov/project-details/10672028) (R36); PI: Amy L McMenamin; Organization: Columbia University Health Sciences; Grant Start Date: June 1, 2023; Assesses care environments for NPs to understand how primary care practices can support NPs providing complex care for people with multiple chronic conditions (MCCs), particularly in communities with low socioeconomic resources. Investigates the relationship between NP care environments (e.g., level of support for NP practice, collegiality between clinicians, and an organizational understanding of the NP role), community characteristics (i.e., socioeconomic resources and availability of primary care), and acute care utilization among older adults with MCCs.
The Role of Nurse Practitioners in Improving Access to Primary Care (https://reporter.nih.gov/project-details/10595008) (R03); PI: Hannah Toby Neprash; Organization: University of Minnesota; Grant Start Date: April 1, 2022; Develops a national database of all-payer claims and EHR data to examine how much adding NPs to primary care teams increases access to care, particularly for patient populations that have traditionally faced barriers to access.; Webinar icon Learn more about this study in a recent NCEPCR webinar: Research Methods for Studying the Primary are Workforce (https://www.ahrq.gov/ncepcr/about/pcr-webinar-series/research-pc-workforce.html)

#### Using AI for Documentation

One study looks at the value of AI for reducing burden to support the primary care workforce.

[image] Guiding the Safe and Effective Integration of Ambient Digital Scribes into Primary Care (https://reporter.nih.gov/project-details/11038097) (R03); PI: Joshua Biro; Organization: Medstar Health Research Institute; Grant Start Date: September 30, 2024; Aims to develop a prototype guide for the safe and effective use of AI documentation technologies, known as Ambient Digital Scribes (ADSs), in primary care. ADSs have the potential to reduce documentation burden for clinicians – a leading cause of burnout. This study uses retrospective data analyses and interviews with primary care clinicians and patients to understand the barriers and facilitators to successful ADS use and build foundational knowledge about how ADSs can be successfully integrated into the primary care workflow. With input from a range of key actors, this study aims to develop a prototype guide designed to support ADS implementation and use at healthcare organizations of all sizes and types, including rural primary care clinics and FQHCs.

### Initiatives and Resources

AHRQ released the following resources related to the primary care workforce in FYs 2023 and 2024.

A Pragmatic Approach to Identifying and Profiling Primary Care Clinicians and Primary Care Practices in the USA

The article (https://link.springer.com/article/10.1007/s11606-024-08627-8) “A Pragmatic Approach to Identifying and Profiling Primary Care Clinicians and Primary Care Practices in the USA” in the Journal of General Internal Medicine, was written by current and past AHRQ staff. Using the IQVIA OneKey Healthcare Professional database, the framework described in this article prescribes sequential steps to identify primary care clinicians by cross-examining clinician specialties and organizational affiliations and then identifying primary care practices based on organizational types and presence of primary care clinicians.

Burnout in Primary Care: Assessing and Addressing It in Your Practice

This image shows the cover of a resource entitled “Burnout in Primary Care: Assessing and Addressing it in Your Practice.

This resource (https://www.ahrq.gov/sites/default/files/wysiwyg/evidencenow/tools-and-materials/burnout-in-primary-care.pdf) is focused what can be done to address clinician and staff burnout in primary care at an organizational or practice level. The resource includes tools and guidance that primary care administrators, leaders, and clinicians can use to address burnout within their organization, including validated assessment tools to measure burnout within an organization and identify its root causes, and steps individual organizations can take to tackle burnout based on their unique organizational needs.

NCEPCR Webinar: Research Methods for Studying the Primary Care Workforce

This image shows a screenshot from the NCEPCR webinar entitled “Research Methods for Studying the Primary care Workforce.”

NCEPCR hosted a webinar (https://www.ahrq.gov/ncepcr/about/pcr-webinar-series/research-pc-workforce.html) on research about the primary care workforce in May 2024. In the webinar, three AHRQ grantees presented methods and findings from their research about the optimal structure and composition of primary care teams and measuring the impacts of adding nurse practitioners into primary care.

This is a photo of primary care researcher, Daniel Tawfik.

In an AHRQ primary care research grant led by PI Daniel Tawfik, researchers have developed a prediction tool to identify primary care practices at high risk of clinician burnout. Instead of relying on clinician surveys that increase burden, the tool enables real-time reports using already collected EHR data to help predict and prevent burnout before it occurs. Practices identified as high-risk can implement tailored process improvements to avoid the negative impacts of burnout on clinician well-being and patient care and safety.

To learn more about this study and how you can access this burnout prediction tool read the NCEPCR Impact Story: Enabling Real-Time Identification of Burnout Risk Among Clinicians in Primary Care Practices (https://www.ahrq.gov/sites/default/files/wysiwyg/ncepcr/about/impact-stories/enabling-real-time.pdf).

## Public Health and Community Integration

Healthcare, prevention, and the promotion and facilitation of healthy behaviors are not limited to healthcare institutions. Primary care can more effectively provide comprehensive, whole-person healthcare by working with the communities in which they are located, including developing partnerships with schools, workplaces, and community-based organizations and services. Community health workers – the community members that work with a health clinic – often help to build and maintain these clinical-community partnerships.^(35)^ While medical care focuses on supporting patients’ individual health needs, public health focuses on the prevention and control of infectious and chronic diseases for an entire population.^(36)^ Public health agencies support primary care through disease surveillance, emergency preparedness and response, and community-wide promotion of physical and mental health efforts. Close collaboration between public health and primary care can help to save resources, improve individual patient outcomes, and improve population health outcomes.^(37)^

In this section, we describe AHRQ primary care research grants focused on developing linkages between primary care and the community, including public health organizations.

### Grants

Across the AHRQ primary care research grants with active funding in FYs 2023 and 2024, three grants focus on public health and community integration. This includes one R01 (Research Projects), one R18 (Research Demonstration and Dissemination Project), and one K08 (Mentored Clinical Scientist Development Award).

There are an additional 6 grants with some focus on Public Health and Community Integration, which are described in other topic area sections, including one in Healthcare Systems and Infrastructure, one in Practice and Quality Improvement, one in Healthcare Disparities, one in Behavioral Health and Substance Use Disorders, one in Digital Healthcare, and one in Person-Centered Care.

We summarize the three grants focused on public health and community integration below.

[image] Healthy Hearts in Manufacturing: Improving Cardiovascular Care in Worksite Health Clinics (https://reporter.nih.gov/project-details/10915578) (R18); PI: Meghan McHugh; Organization: Northwestern University at Chicago; Grant Start Date: September 1, 2023; Examines the effectiveness of worksite health clinics providing hypertension control and smoking cessation interventions to improve cardiovascular care in manufacturing communities. Evidence-based interventions are drawn from AHRQ’s EvidenceNOW model, a blueprint for delivering external support to primary care practices to improve primary care delivery. Measurements collected include facilitators and barriers to sustainability, the effectiveness of the interventions, and budget implications.
Implementing Personalized Cross-Sector Transitional Care Management to Promote Care Continuity, Reduce Low Value Utilization, and Reduce the Burden of Treatment for High-Need, High-Cost Patients (https://reporter.nih.gov/project-details/10814793) (R01); PI: Sharon Hewner; Organization: State University of New York at Buffalo; Grant Start Date: April 1, 2021; Tests a personalized, cross-sector, transitional care management model in primary care and behavioral health settings to improve care coordination across settings using a health information exchange infrastructure for high-need/high-cost patients or patients with multiple chronic conditions, functional disabilities, and/or social needs.; Magnifying glass icon Learn more about this study in a Primary Care Research Profile: Supporting Patients with Complex Medical and Social Needs During Transitions in Care (https://www.ahrq.gov/sites/default/files/wysiwyg/ncepcr/about/profiles/profile_hewner.pdf)
[image] Latino School Readiness: Engaging Pediatric and Early Childhood Systems to Adapt and Pilot Family-Centered Primary Care Interventions (https://reporter.nih.gov/project-details/10791850) (K08); PI: Jamie Peterson; Organization: Oregon Health & Science University; Grant Start Date: March 1, 2023; Develops and pilots a package of pediatric clinic-based school readiness interventions that are specifically designed to target the needs and desires of Latino families.

### Initiatives and Resources

AHRQ shares resources for clinical-community partnerships (https://www.ahrq.gov/prevention/resources/chronic-care/index.html) and SDOH resources (https://www.ahrq.gov/sdoh/resources.html) for clinicians and researchers. There were no new public health and community integration initiatives or resources related to primary care released in FYs 2023 and 2024.