# 9 References

1 Carr A N D, Alford C, Chang C, Banez L, Iyer S, Wittenberg K, Zhan C, O’Malley P, Umscheid CA. AHRQ Evidence-Based Practice Center Program Research Gaps Summary: Primary Care. Rockville, MD: Agency for Healthcare and Research Quality 2022 March. Report No.: Contract No.: 22- EHC017.
2 Bierman AS T S, McNellis RJ. Realizing the Dream: The Future of Primary Care Research. Annals of Family Medicine 2022;20(2). doi: 10.1370/afm.2788.
3 Healthcare Research and Quality Act of 1999, (1999).
4 Rockwell M., Holtrop J, Eden A, McNellis R, Leal A, Bierman A, Kato E. Mapping AHRQ’s 30-Year Investment in Primary Care Research (1990-2020). Rockville, MD: Agency for Healthcare Research and Quality; January 2024. AHRQ Pub. No. 24-0016.
5 About AHRQ’s National Center for Excellence in Primary Care Research [cited 2023 November 1]. Available from: https://www.ahrq.gov/ncepcr/about/index.html.
6 HHS IS TAKING ACTION TO STRENGTHEN PRIMARY CARE 2023 [cited 2023 December 11]. Available from: https://www.hhs.gov/sites/default/files/primary-care-issue-brief.pdf.
7 AHRQ’s 30th Anniversary Primary Care Research Conference: Proceedings [cited 2023 May 11]. Available from: https://www.ahrq.gov/ncepcr/about/primary-care-research-conference-proceedings.html.
8 Basics of Quality Improvement [cited 2023 June 5]. Available from: https://www.aafp.org/family-physician/practice-and-career/managing-your-practice/quality-improvement-basics.html.
9 Quality Improvement of Primary Care [cited 2023 Jun 5]. Available from: https://www.ahrq.gov/research/findings/factsheets/quality/qipc/index.html.
10 Disseminating Evidence into Practice [cited 2023 June 5]. Available from: https://www.ahrq.gov/ncepcr/research/disseminating-evidence/index.html.
11 The EvidenceNOW Model: Providing External Support for Primary Care [cited 2023 June 5]. Available from: https://www.ahrq.gov/evidencenow/model/index.html.
12 EvidenceNOW: Building State Capacity [cited 2023 June 5]. Available from: https://www.ahrq.gov/evidencenow/projects/state/index.html.
13 EvidenceNOW: Managing Unhealthy Alcohol Use [cited 2023 June 5]. Available from: https://www.ahrq.gov/evidencenow/projects/alcohol/index.html.
14 EvidenceNOW: Managing Urinary Incontinence [cited 2023 June 5]. Available from: https://www.ahrq.gov/evidencenow/projects/urinary/index.html.
15 Practice Facilitation [cited 2023 June 5]. Available from: https://www.ahrq.gov/evidencenow/practice-facilitation/index.html.
16 Obtaining and Using Data in Practice: A Handbook for Health IT Advisors and Practice Facilitators [cited 2023 June 5]. Available from: https://www.ahrq.gov/ncepcr/tools/transform-qi/deliver-facilitation/healthit-advisor-handbook.html.
17 Primary Care Practice-Based Research Networks [cited 2023 June 5]. Available from: https://www.ahrq.gov/research/findings/factsheets/primary/pbrn/index.html.
18 PCMH Foundations [cited 2023 May 18]. Available from: https://www.ahrq.gov/ncepcr/tools/pcmh/implement/foundations.html (https://archive.ahrq.gov/ncepcr/tools/pcmh/implement/foundations.html).
19 Health Care/System Design [cited 2023 May 18]. Available from: https://www.ahrq.gov/ncepcr/tools/redesign/index.html (https://archive.ahrq.gov/ncepcr/tools/redesign/index.html).
20 Care Coordination [cited 2023 May 18]. Available from: https://www.ahrq.gov/ncepcr/care/coordination.html.
21 Independent Physician Associations (IPAs) Definition [cited 2023 May 18]. Available from: https://www.aafp.org/about/policies/all/independent-physician-associations.html.
22 Medical Expenditure Panel Survey [cited 2023 May 18]. Available from: https://meps.ahrq.gov/mepsweb/about_meps/survey_back.jsp.
23 What is Digital Health? [cited 2023 May 26]. Available from: https://www.fda.gov/medical-devices/digital-health-center-excellence/what-digital-health.
24 Lyles CR, Nguyen, O. K., Khoong, E. C, Aguilera, A., Sarkar, U,. Multilevel Determinants of Digital Health Equity: A Literature Synthesis to Advance the Field. Annual Review of Public Health. 2023;44:383–405. doi: 10.1146/annurev-publhealth-071521-023913.
25 What is Clinical Decision Support? [cited 2023 May 26]. Available from: https://www.healthit.gov/topic/safety/clinical-decision-support.
26 What Are Patient-Generated Health Data? [cited 2023 May 26]. Available from: https://www.healthit.gov/topic/scientific-initiatives/pcor/patient-generated-health-data-pghd.
27 National Academies of Sciences Engineering, and Medicine. 2021. Implementing High-Quality Primary Care: Rebuilding the Foundation of Healthcare. Available from: https://www.nationalacademies.org/our-work/implementing-high-quality-primary-care.
28 Topic: Patient-Centered Healthcare [cited 2023 June 28]. Available from: https://www.ahrq.gov/topics/patient-centered-healthcare.html.
29 About CAHPS [cited 2023 June 29]. Available from: https://www.ahrq.gov/cahps/about-cahps/index.html.
30 Development of the CAHPS Clinican & Group Survey [cited 2023 June 29]. Available from: https://www.ahrq.gov/cahps/surveys-guidance/cg/about/Develop-CG-Surveys.html.
31 CAHPS Clinican & Group Survey [cited 2023 June 29]. Available from: https://www.ahrq.gov/cahps/surveys-guidance/cg/index.html.
32 Becerra X P A, Hafajee RL, Contreras J, Barkof, A, O’Connell D, . Addressing The Nation’s Behavioral Health Crisis: An HHS Roadmap to Integrate Behavioral Health. Health Afairs Forefront 2022. doi: 10.1377/forefront.20221130.118858.
33 What is Integrated Behavioral Health? [cited 2023 May 8]. Available from: https://integrationacademy.ahrq.gov/about/integrated-behavioral-health.
34 Behavior and Mental Health [cited 2023 May 8]. Available from: https://www.ahrq.gov/ncepcr/tools/mental/index.html (https://archive.ahrq.gov/ncepcr/tools/mental/index.html).
35 Professional Practices [cited 2023 May 8]. Available from: https://integrationacademy.ahrq.gov/products/professional-practices?_gl=1*1kdaocx*_ga*MTIwNzU5OTA3My4xNjc3NTk1MDYx*_ga_1NPT56LE7J*MTY4MDU0MTk5My4yNy4xLjE2ODA1NDQxMDYuMC4wLjA.
36 Strategies for Integrating Behavioral Health and Primary Care [cited 2023 May 8]. Available from: https://efectivehealthcare.ahrq.gov/products/strategies-integrating-behavioral-health/protocol#field_report_title_1 (https://effectivehealthcare.ahrq.gov/products/strategies-integrating-behavioral-health/protocol#field_report_title_1).
37 The Academy for Integrating Behavioral Health and Primary Care [cited 2023 May 8]. Available from: https://www.ahrq.gov/cpi/about/otherwebsites/integrationacademy.ahrq.gov/index.html.
38 About AHRQ’s Six Building Blocks: A Team-Based Approach To Improving Opioid Management in Primary Care Program [cited 2023 May 8]. Available from: https://www.ahrq.gov/patient-safety/settings/ambulatory/improve/six-building-blocks-about.html.
39 What is Health Equity? [cited 2023 July 19]. Available from: https://www.cdc.gov/healthequity/whatis/index.html#:~:text=Health%20equity%20is%20the%20state,health%20and%20health%20care%3B%20and.
40 O’Kane M, Agrawal, S., Binder, L., Dzau, V., Gandhi, TK., Harrington, R., Mate K., McGann, P., Meyers, D., Rosen, P., Schreiber M., Schummers D. An Equity Agenda for the Field of Health Care Quality Improvement NAM Perspectives. 2021. doi: 10.31478/202109b.
41 Henry TL B J, St. Louis J, Bruno R, Oronce CA, Georgeson A, Ragunanthan B, Green MM, Doshi N, Hufstetler AN. Health Equity: The Only Path Forward for Primary Care. Annals of Family Medicine. 2022;20(2):175–8. doi: 10.1370/afm.2789.35165088
42 National Healthcare Quality and Disparities Reports [cited 2023 June 14]. Available from: https://www.ahrq.gov/research/findings/nhqrdr/index.html.
43 Shi L. The impact of primary care: a focused review. Scientifica (Cairo). 2012;2012:432892. Epub 2012/01/01. doi: 10.6064/2012/432892. PubMed PMID: 24278694; PubMed Central PMCID: PMCPMC3820521.24278694
44 Jabbarpour Y, Petterson, S, Jetty A, Byun H. The Health of US Primary Care: A Baseline Scorecard Tracking Support for High-Quality Primary Care. Robert Graham Center February 2023.
45 Primary Care Workforce: Projections, 2020-2035. National Center for Health Workforce Analysis, November, 2022.
46 Stressed Out and Burned Out: The Global Primary Care Crisis [cited 2023 May 10]. Available from: https://www.commonwealthfund.org/publications/issue-briefs/2022/nov/stressed-out-burned-out-2022-international-survey-primary-care-physicians?utm_source=pocket_saves.
47 Family Physician Burnout, Well-Being, and Professional Satisfaction (Position Paper) [cited 2023 May 10]. Available from: https://www.aafp.org/about/policies/all/family-physician-burnout.html.
48 Taking Action Against Clinician Burnout: A Systems Approach to Professional Well-Being. Washington, DC: National Academy of Sciences, Engineering, and Medicine 2019.
49 Edwards ST, Marino M, Balasubramanian BA, Solberg LI, Valenzuela S, Springer R, . Burnout Among Physicians, Advanced Practice Clinicians and Staf in Smaller Primary Care Practices. J Gen Intern Med. 2018;33(12):2138–46. Epub 2018/10/03. doi: 10.1007/s11606-018-4679-0. PubMed PMID: 30276654; PubMed Central PMCID: PMCPMC6258608.30276654
50 Robert Wood Johnson Foundation. 2019. Medicaid’s Role in Addressing Social Determinants of Health. Available from: https://www.rwjf.org/en/insights/our-research/2019/02/medicaid-s-role-in-addressing-social-determinants-of-health.html.
51 SDOH & Practice Improvement [cited 2023 May 24]. Available from: https://www.ahrq.gov/sdoh/practice-improvement.html.
52 Holtrop JS D M. Primary Care Research Is Hard to Do During COVID-19: Challenges and Solutions. Annals of Family Medicine. 2022;20(6). doi: 10.1370/afm.2889. PubMed Central PMCID: PMCPMC9705050.
53 AHRQ COVID-19 Resources [cited 2023 June 8]. Available from: https://www.ahrq.gov/coronavirus/index.html.
54 COVID-19 Research Grant Awards [cited 2023 June 8]. Available from: https://www.ahrq.gov/coronavirus/grants.html.
55 Patient Safety [cited 2023 June 22]. Available from: https://www.who.int/news-room/fact-sheets/detail/patient-safety.
56 Patient Safety in Primary Care [cited 2023 June 22]. Available from: https://psnet.ahrq.gov/perspective/patient-safety-primary-care.
57 Bouck Z C A, Ivers NM, Kerr EA, Chu C, Ferguson J, Martin D, Tpper J, Austin PC, Cram P, Levinson W, Bhatia S. Association of Low-Value Testing with Subsequent Health Care Use and Clinical Outcomes Among Low-Risk Primary Care Outpatients Undergoing and Annual Health Examination JAMA Internal Medicine 2020;180(7):973–83. doi: doi:10.1001/jamainternmed.2020.1611.32511668
58 Mossburg SE D P, O’Malley P, McNellis B, Chew E. Primary Care and Patient Safety: Opportunities at the Interface 2022. Available from: https://psnet.ahrq.gov/perspective/primary-care-and-patient-safety-opportunities-interface.
59 Agency for Healthcare Research and Quality. 2018. The Guide to Improving Patient Safety in Primary Care Settings by Engaging Patients and Families. Available from: https://www.ahrq.gov/sites/default/files/wysiwyg/professionals/quality-patient-safety/patient-family-engagement/pfeprimarycare/pfepc-fullguide-final508.pdf?
60 Center for Quality Improvement and Patient Safety (CQuIPS) [cited 2023 June 22]. Available from: https://www.ahrq.gov/cpi/centers/cquips/index.html.
61 AHRQ’s Healthcare-Associated Infections Program [cited 2023 October 10]. Available from: https://www.ahrq.gov/hai/index.html.
62 Toolkit to Improve Antibiotic Use in Ambulatory Care [cited 2023 June 22]. Available from: https://www.ahrq.gov/antibiotic-use/ambulatory-care/index.html.
63 AHRQ Safety Program for Improving Antibiotic Use Agency for Healthcare Research and Quality.
64 Patient Safety Organization (PSO) Program [cited 2023 October 10]. Available from: https://pso.ahrq.gov/?_gl=1*18cbidi*_ga*MTk3MzI5OTg5Ni4xNjc4NDgwNzg5*_ga_1NPT56LE7J*MTY4NzQ1MjkxMC43MS4xLjE2ODc0NTQ1NDUuNjAuMC4w.
65 Common Formats [cited 2023 June 22]. Available from: https://pso.ahrq.gov/common-formats.
66 Overview [cited 2023 June 22]. Available from: https://pso.ahrq.gov/common-formats/overview.
67 Efective Health Care Program History [cited 2023 July 17]. Available from: https://efectivehealthcare.ahrq.gov/about/history (https://effectivehealthcare.ahrq.gov/about/history).
68 Evidence-based Practice Centers [cited 2023 July 17]. Available from: https://efectivehealthcare.ahrq.gov/about/epc (https://effectivehealthcare.ahrq.gov/about/epc).
69 Celebrating 25 Years of AHRQ’s Evidence-based Practice Center Program [cited 2023 July 17]. Available from: https://efectivehealthcare.ahrq.gov/about/epc-25-years (https://effectivehealthcare.ahrq.gov/about/epc-25-years).
70 About the USPSTF [cited 2023 July 17]. Available from: https://www.uspreventiveservicestaskforce.org/uspstf/about-uspstf.
71 Task Force at a Glance [cited 2023 July 17]. Available from: https://www.uspreventiveservicestaskforce.org/uspstf/about-uspstf/task-force-at-a-glance.
72 APTR-AHRQ Preventive Medicine Residency Rotations [cited 2023 July 17]. Available from: https://www.aptrweb.org/mpage/Rotations.
73 Patient-Centered Outcomes Research Clinical Decision Support [cited 2023 July 17]. Available from: https://cds.ahrq.gov/.
74 Clinical Decision Support Innovation Collaboration (CDSiC) [cited 2023 July 17]. Available from: https://digital.ahrq.gov/ahrq-funded-projects/clinical-decision-support-innovation-collaborative-cdsic.
75 Welcome to CDS Connect [cited 2023 July 17]. Available from: https://cds.ahrq.gov/cdsconnect.