# Acknowledgments

The authors would like to thank Kevin Grumbach, MD and Yalda Jabbarpour, MD who provided senior guidance to our team. We would also like to thank our colleagues, who provided valuable direction and input on the development of this report. This includes Jan De La Mare, MPAff and Gail Makulowich at AHRQ; and Ann Loeffler, MSPH at Abt.