# 4 AHRQ’s Recent Primary Care Grants and Resources

In this section we share information about AHRQ’s primary care grants, initiatives, and resources in 2021 and 2022. This information is organized into key topic areas and additional topic areas. In the tables throughout this section, we include short summaries for each of the 124 unique AHRQ primary care relevant grants and the 2 COVID-19 add-on studies. We include links to Project Profiles and Emerging Research Spotlights in Appendix D for more detailed summaries of potentially high-impact grants. Grant titles in the tables link to additional information (including publications) on the NIH RePORTER (https://report.nih.gov/) website.

[image] Grants with a focus on health equity, which is an important cross-cutting topic, are indicated throughout the report with this icon

## Key Topic Areas

The information in this section is organized into the eight areas identified by AHRQ as the topics of key interest for their forthcoming primary care research agenda. Each grant is described in the section that best matches the main focus of the work (as determined by the Abt team). The key topic areas are:

■ Practice and Quality Improvement
■ Healthcare Systems and Infrastructure
■ Digital Healthcare
■ Person-Centered Care
■ Behavioral Health and Substance Use Disorders
■ Health Equity
■ Primary Care Workforce
■ Public Health and Community Integration

Below we provide information about the AHRQ grants, initiatives, and resources for each of these key topic areas.

### Practice and Quality Improvement

The American Academy of Family Physicians defines quality improvement (QI) as “a systematic, formal approach to the analysis of practice performance and eforts to improve performance.”^(8)^ Primary care practices with a strong QI orientation seek to continuously improve their own processes of care and improve patient health outcomes.^(9)^ Practices engaged in QI identify areas of their performance in need of improvement, set goals for the clinical and practice performance outcomes they aim to achieve, and identify the appropriate methods or approaches to achieve those goals.

Implementing primary care quality improvement on a national scale requires efectively disseminating the latest evidence to practices. It also requires that practices have the capacity and skills to engage in QI activities based on that evidence. AHRQ funds patient-centered outcomes research to generate new evidence for primary care, as well as dissemination and implementation (D&I) research on how evidence-based practices are translated and used in clinical settings.^(10)^ AHRQ also works to disseminate evidence to practices and clinical teams, and develops QI implementation tools and resources to help practices implement evidence-based practices to improve the care of their patients.

Below we include a summary of AHRQ’s grants, contracts, and resources that focus on practice and quality improvement in primary care.

[image] Grants with a focus on health equity are indicated with this icon

#### Grants

Thirty-three AHRQ primary care grants actively funded during FYs 2021 and 2022 were mainly focused on practice and quality improvement. This included 12 R18s (Research Demonstration and Dissemination Projects), 9 U18s (Research Demonstration / Cooperative Agreements), 5 R01s (Research Projects), 3 R13s (Support for Conferences and Scientific Meetings), 2 R03s (Small Research Project Grants), 1 K01 (Research Career Program), and 1 K08 (Mentored Clinical Scientist Development Award). Another 22 grants included some focus on the topic of practice and quality improvement and are described in other sections of this report, including Person-Centered Care (10), Digital Healthcare (9), Healthcare Systems and Infrastructure (1), Health Equity (1), and Primary Care Workforce (1).

Below are tables, organized by subtopic, which include short summaries of each of the 33 primary care grants focused mainly on practice and quality improvement. The seven subtopics include improving care and prevention for cardiovascular disease or diabetes, improving the quality of care for other specific health conditions, electronic health record (EHR)-based tools to improve care for sexual and reproductive health, practice improvements to improve patient safety, impact of care teams on quality of care, conference grants, and grants from the EvidenceNOW initiative.

##### Improving Care and Prevention for Cardiovascular Disease or Diabetes

Four studies examine eforts to improve evidence-based care for cardiovascular disease or diabetes management and prevention.

Assessing the Use of Practice Facilitation to Optimize Scale Up of CDS for Hypertension Management (R18) (https://reporter.nih.gov/project-details/10374712)
PIs: Hang Pham-Singer; Saul B. Blecker; Organization: Fund for Public Health in New York, Inc.; Examines if receiving practice facilitation would improve the use of a hypertension focused clinical decision support to effectively improve blood pressure control rates in small primary care practices. (See more information about practice facilitation, including resources in Initiatives and Resources below).
Improving Recognition and Management of Hypertension in Youth: Comparing Approaches for Extending Efective CDS for Use in a Large Rural Health System (R18) (https://reporter.nih.gov/project-details/10454225)
PIs: Elyse Olshen Kharbanda; Catherine Pastorius Benziger; Organization: HealthPartners Institute; Compares high and low intensity interventions to implement an EHR-linked clinical decision support in rural primary care practices to provide evidence-based clinical care recommendations for blood pressure management in youth.
[image] Adapting Guideline Implementation to Local Environments (AGILE) in Primary Care Afer Telehealth Expansion (K01) (https://reporter.nih.gov/project-details/10429331)
PI: Edmond Ramly; Organization: University of Wisconsin—Madison; School of Medicine, Family Medicine; Aims to develop a customizable toolkit for implementing cardiovascular disease guidelines in primary care afer telehealth expansion. The toolkit includes a menu of options to help practices address specific local barriers without requiring the engagement of an expert for a costly tailoring process.
Prevent Diabetes Mellitus (PreDM) Clinical Decision Support Intervention in Community Health Centers (R18) (https://reporter.nih.gov/project-details/9957044)
PI: Matthew James O’Brien; Organization: Northwestern University at Chicago; School of Medicine, Internal Medicine; Evaluates a clinical decision support-based intervention to improve care at community health centers for patients with prediabetes.

##### Improving the Quality of Care for Other Specific Health Conditions

Three grants examine improving the quality of care for other health conditions.

Reframing Optimal Management of Pain and Opioids in Older Adults (R18) (https://reporter.nih.gov/project-details/10463630)
PIs: Daniel William Berland; Christine Elizabeth Stanik; Organization: University of Michigan at Ann Arbor; School of Medicine, Internal Medicine; Implements practice improvements for safely prescribing opioids or alternative medications for pain management in older adults in primary care. The project takes a multi-faceted approach, including educating and supporting prescribers, academic detailing, and use of electronic health record technology.
Enhanced Kidney Follow-up for AKI Survivors in Care Transitions (the ACT Study) (R03) (https://reporter.nih.gov/project-details/10395486)
PI: Erin Frazee Barreto; Organization: Mayo Clinic Rochester; This pilot feasibility trail evaluates a program that supports patients discharged from the hospital to home afer an episode of acute kidney injury. The findings from this study can assist primary care clinicians with providing high-quality, well-coordinated, and patient-centered care for survivors of AKI.; Read Research Profile #1
Improving Evidence-based Care for Cancer Patients (R01) (https://reporter.nih.gov/project-details/9831167)
PI: Graham W. Warren; Organization: Medical University of South Carolina; School of Medicine, Radiation-Diagnostic /Oncology; Evaluates the use of an “opt-out” (rather than “opt-in”) strategy for increasing enrollment of cancer patients who smoke into an evidence-based smoking cessation program. While this project is not focused on primary care, the findings can help advise how primary care practices can efectively enroll patients in evidence-based smoking cessation programs.

##### EHR-Based Tools to Improve Care for Sexual and Reproductive Health

Three studies look at EHR-based tools to improve care for sexual and reproductive health. More studies focused on EHR-based tools, including clinical decision supports, are included in the Digital Healthcare section.

EHR-based Screening and Intervention for Intimate Partner Violence (R18) (https://reporter.nih.gov/project-details/9985868)
PIs: Leslie A. Lenert; Alyssa Ann Rheingold; Organization: Medical University of South Carolina; School of Medicine, Public Health & Preventive Medicine; Evaluates the implementation of an EHR-based decision support program to support universal screening of women for intimate partner violence (IPV) in primary care clinics. The decision support program includes a referral to a national IPV counseling hotline for those who screen positive.
Implementation of Electronic Health Screening in Primary Care to Improve STI Testing (R18) (https://reporter.nih.gov/project-details/10018013)
PI: Fahd Aqeeb Ahmad; Organization: Washington University; School of Medicine; Pediatrics; Integrates an electronic risk assessment tool into four pediatric primary care clinics to help identify adolescents at-risk for sexually transmitted infections during annual preventive maintenance visits.; Read Research Profile #2
The Community Health Center - Reproductive Life Plan (CHC-RLP) Project (R03) (https://reporter.nih.gov/project-details/10216581)
PI: Lisa Marie Masinter; Organization: Alliance Chicago; Aims to use structured reproductive health assessments, known as reproductive life plans, embedded in the EHR to improve reproductive health care for women in a primary care setting.

##### Practice Improvements to Improve Patient Safety

Three grants focus on practice improvement eforts to improve patient safety. More about AHRQ research and initiatives related to patient safety in primary care can be found in the Patient Safety section of this report.

Implementing Telemedicine to Improve Appropriate Antibiotic Prescribing for Acute Respiratory Tract Infections (R01) (https://reporter.nih.gov/project-details/10419727)
PIs: Tamar Barlam; Mari-Lynn Drainoni; Organization: Boston Medical Center; Examines if telehealth visits can be used to improve the management of acute respiratory tract infections, including reducing inappropriate prescribing of antibiotics in ambulatory care settings.
Medical Reversals: De-Implementing Inefective and Unsafe Treatments (R01) (https://reporter.nih.gov/project-details/9986799)
PI: Pinar Karaca-Mandic; Organization: University of Minnesota; School of Public Health, Public Health & Preventive Medicine; Looks at the de-implementation of treatments that have been found to be inefective or unsafe. The research team examines the diferences in de-implementation across diferent physicians and health care delivery organizations, taking into account varying characteristics and market environments. While this project is not focused exclusively on primary care, the findings can be used to understand barriers and facilitators to de-implementing the use of ineffective and unsafe treatments and screenings in a primary care setting.
ExPERTS-PC: Engaging Patients in Event ReporTing for Safety in Primary Care (K08) (https://reporter.nih.gov/project-details/10284478)
PI: Anjana Estelle Sharma; Organization: University of California, San Francisco; School of Medicine, Family Medicine; Develops a tool for patients to report adverse drug events (ADEs) to their ambulatory care teams. The research team will use natural language processing to identify the patient, caregiver, and healthcare team related causes of ADEs from the reports of a multistate Patient Safety Organization. Using the information about identified causes, the team will develop a prototype of a patient-initiated ADE reporting system using text messaging, and will conduct feasibility testing with patients, family members, and primary care clinic staf.; Learn more about this study in a recent NCEPCR webinar: Innovative Use of Technology for Primary Care Delivery (https://www.ahrq.gov/ncepcr/about/pcr-webinar-series/innovative-use.html).

##### Impact of Care Teams on Quality of Care

Two grants study the impact of care teams on the quality of care.

Impact of Team Configuration and Team Stability on Primary Care Quality (R01) (https://reporter.nih.gov/project-details/10146331)
PI: Sylvia J. Hysong; Organization: Baylor College; School of Medicine, Internal Medicine; Uses Veterans Health Administration data to conduct network analysis to understand the impact of team configurations on quality in primary care. The study aims to develop guidance on the best configurations of primary care teams for delivering high-quality and patient-centered care.; Read Research Profile #3
Primary Care Physician-Staf Dyads (“Teamlets”): A Simple, Eficient Means to Improve Healthcare Quality and Decrease Cost? (R01) (https://reporter.nih.gov/project-details/9928899)
PI: Lawrence Peter Casalino; Organization: Weill Medical College of Cornell University; School of Medicine; Looks at the use of “teamlets” in primary care. Teamlets are dyads that include a physician and another staf person who consistently work together to provide care. This study looks at the prevalence of teamlets in primary care, examines the relationship between teamlets and quality, and identifies the characteristics of high-performing teamlets.

##### Conference Grants

There are three conference grants on this topic area of Practice and Quality Improvement, described below. More information about practice-based research networks and practice facilitation (the foci of two of the conference grants) is included in Initiatives and Resources.

Advancing & Improving Measurement and Value in Primary Care (The AIM-PC Starfield Summit) (R13) (https://reporter.nih.gov/project-details/10294316)
PI: Beth A Bortz; Organization: Virginia Center for Health Innovation; The 5th Starfield Summit aims to bring together a diverse group of leaders in primary care research and policy to address the challenge of measurement in primary care with a focused discussion on increasing the value of primary care through measurement and reducing low value care.
National Practice-Based Research Network Conferences 2020 to 2022 (R13) (https://reporter.nih.gov/project-details/10263152)
PI: Donald E Nease; Organization: North American Primary Care Research Group (NAPCRG); This annual conference brings together practice-based research network (PBRN) researchers to share their research strategies, methods, innovations, and results to advance the science of primary care research and improve the quality of primary care.
International Conference on Practice Facilitation 2020, 2021, 2022 (R13) (https://reporter.nih.gov/project-details/10194468)
PI: Zsolt J Nagykaldi; Organization: North American Primary Care Research Group (NAPCRG); This conference serves as a learning community for primary care practice facilitators and works to establish a professional society for professionals working in this field.

##### EvidenceNOW Grants

Among the 33 grants in the Practice and Quality Improvement section, there were 15 grants and cooperative agreements from across the three active EvidenceNOW initiatives: EvidenceNOW: Building State Capacity, EvidenceNOW: Managing Unhealthy Alcohol Use, and EvidenceNOW: Managing Urinary Incontinence. For additional information about these initiatives overall and the EvidenceNOW model, please see Initiatives and Resources.

EvidenceNOW: Building State Capacity
[image] The Alabama Cardiovascular Cooperative: Supporting Cardiovascular Risk Reduction in Primary Care (U18) (https://reporter.nih.gov/project-details/10323063)
PI: Andrea L Cherrington; Organization: University of Alabama at Birmingham; School of Medicine, Internal Medicine; This grant funds the Alabama Cardiovascular Cooperative to coordinate statewide eforts to improve cardiovascular risk and reduce disparities. Additionally implements a heart health improvement project in 60 primary care clinics throughout Alabama to improve rates of blood pressure control and screening for smoking status.
[image] Tennessee Heart Health Network: Implementing Patient-Centered Practices in Primary Care to Improve Cardiovascular Health (U18) (https://reporter.nih.gov/project-details/10361466)
PIs: James E Bailey; Benjamin S Heavrin; Organization: University of Tennessee Health Science Center; School of Medicine, Internal Medicine; This grant funds the Tennessee Heart Health Network (THHN), which will leverage existing infrastructure to identify and implement evidence-based interventions to improve quality of care for cardiovascular disease in primary care across the State. The THHN will specifically target hypertension control and smoking cessation to help reduce disparities in cardiovascular outcomes.
[image] Achieving Outstanding Cardiovascular Health Outcomes for All Ohioans: A Statewide Cardiovascular Health Collaborative (Cardio-OH) (U18) (https://reporter.nih.gov/project-details/10321968)
PIs: Shari Danielle Bolen; Aleece Caron; Organization: Case Western Reserve University; School of Medicine; Internal Medicine; Expands a nascent statewide cardiovascular health collaborative in Ohio and establishes a sustainable external quality improvement (QI) support infrastructure in the State. The project will also implement and evaluate a QI intervention for heart health that will be co-designed with primary care practices.
[image] Healthy Hearts for Michigan (HH4M): Providing Support to Improve the Heart Health and Help Reduce CVD Disparities by Engagement with Primary Care Practices (U18) (https://reporter.nih.gov/project-details/10323065)
PIs: Anya Day; Theresa L Walunas; Organization: Altarum Institute; The Healthy Hearts for Michigan (HH4M) project establishes a statewide cooperative in MI to provide QI support to help primary care practices implement interventions to improve hypertension management and tobacco cessation. These efforts will be coupled with optimization of health information technology and telehealth approaches to address barriers to access in rural parts of the State.

EvidenceNOW: Managing Unhealthy Alcohol Use
[image] Practice Facilitation to Promote Evidence-based Screening and Management of Unhealthy Alcohol Use in Primary Care (R18) (https://reporter.nih.gov/project-details/10260467)
PI: Alexander H Krist; Organization: Virginia Commonwealth University; School of Medicine, Family Medicine; Brings together 125 primary care practices in 5 regions throughout Virginia to participate in an intervention to implement evidence-based screening, counseling, and treatment for unhealthy alcohol. Practice support includes practice facilitation, education and training, shared learning and best practices, screening and counseling toolkits, data support, and assessment with feedback.
Intervention in Small Primary Care Practices to Implement Reduction in Unhealthy Alcohol usE (INSPIRE) (R18) (https://reporter.nih.gov/project-details/10260395)
PIs: Abel N Kho; Theresa L Walunas; Organization: Northwestern University at Chicago; School of Medicine, Internal Medicine; Tests the feasibility and efectiveness of ofice-based screening for unhealthy alcohol use supported by behavioral and medication-based interventions in primary care practices. Practices receive support for implementation through an integrated platform of education, practice facilitation, and embedded EHR technology.
Facilitating Alcohol Screening and Treatment (FAST), Colorado (R18) (https://reporter.nih.gov/project-details/10260418)
PI: Walter Perry Dickinson; Organization: University of Colorado Denver; School of Medicine, Family Medicine; Conducts a cluster randomized trial to compare approaches for supporting primary care practices to improve their identification and treatment management of unhealthy alcohol use among adults, including screening, brief intervention, medication assisted therapy, and referral to treatment. The two approaches being compared include an in-person practice facilitation intervention and a virtual practice facilitation intervention. The virtual intervention includes an e-learning module to guide the virtual group sessions.
Screening and Management of Unhealthy Alcohol Use in Primary Care: Dissemination and Implementation of PCOR Evidence (R18) (https://reporter.nih.gov/project-details/10259712)
PIs: Darren A Dewalt; Daniel E Jonas; Organization: University of North Carolina Chapel Hill; School of Medicine, Internal Medicine; Aims to determine if primary care practice facilitation can support rapid dissemination and implementation of evidence-based screening, counseling, and medication assisted therapy for unhealthy alcohol use. In addition, the research team aims to test if providing embedded telehealth services accelerates dissemination and implementation for practices with slower uptake.
ANTECEDENT (Partnership to Enhance Alcohol Screening, Treatment, and Intervention) (R18) (https://reporter.nih.gov/project-details/10259696)
PIs: Melinda Marie Davis; John Muench; Organization: Oregon Health & Science University; Medicine; Aims to have practice facilitators help 150 primary care practices in Oregon implement screening and brief intervention (SBI), medication assisted treatment (MAT), and referral to treatment as part of routine care to address unhealthy alcohol use. The study will evaluate the impact of foundational and supplemental implementation support on SBI, MAT, and quality improvement capacity in participating primary care clinics.
The Michigan Sustained Patient-centered Alcohol-Related Care (MI-SPARC) Trial (R18) (https://reporter.nih.gov/project-details/10259683)
PI: Katharine Bradley; Organization: Kaiser Foundation Research Institute; Brings together the expertise of Kaiser Permanente Washington Health Research Institute (KPWHRI) in implementing evidence-based care for treating unhealthy alcohol use with Altarum Institute’s experience efectively engaging small and medium sized primary care practices throughout Michigan in quality improvement eforts. The project will specifically test if involvement in MI-SPARC increases practice use of screening and brief intervention and medication assisted treatment for alcohol use disorder.

EvidenceNOW: Managing Urinary Incontinence
[image] A Practice-based Intervention to Improve Care for a Diverse Population of Women with Urinary Incontinence (U18) (https://reporter.nih.gov/project-details/10377770)
PI: Jennifer Tash Anger; Organization: University of California, San Diego; School of Medicine, Urology; Aims to improve the quality of urinary incontinence care provided to a diverse population of women in primary care, with the goals of improving care and reducing the need for specialty care. Three Southern California medical groups (a total of 60 clinics) will participate in a practice-based incontinence intervention. The intervention will be led by a “clinical champion dyad” including a primary care provider and urologist/urogynecologist from each medical group and will include physician education and performance feedback, electronic decision support, patient education from dedicated advanced practice providers, and an electronic referral service.
Improving Primary Care Understanding of Resources and Screening for Urinary Incontinence to Enhance Treatment (PURSUIT) (U18) (https://reporter.nih.gov/project-details/10377017)
PIs: Alayne Denise Markland; Elizabeth Camille Vaughan; Organization: University of Alabama at Birmingham; School of Medicine, Internal Medicine; Aims to improve access for women Veterans in the southeastern U.S. to evidence-based, nonsurgical treatment for urinary incontinence. Compares the efectiveness of the interactive treatment modality with or without additional urinary incontinence clinical expertise delivered via telehealth in 62 primary care practices that treat women Veterans. Participating practices receive practice facilitation support, training, and health information technology assistance. Researchers explore women Veterans’ and providers’ perceptions of remote urinary incontinence treatment to advise future scalability.
Empowering Women and Providers for Improved Care of Urinary Incontinence: EMPOWER Study (U18) (https://reporter.nih.gov/project-details/10377802)
PIs: Adonis K Hijaz; Goutham Rao; Organization: University Hospitals of Cleveland; Uses an integrated, multilevel approach to address key barriers to diagnosing and managing urinary incontinence in primary care. The approach will be implemented across a large network of primary care practices, and include large-scale screening, empowering patients to discuss urinary incontinence with their providers, provider education and training, practice facilitation through nurse navigation, and a “chatbot” to support patient self-management. The project will also implement a system-based strategy for streamlined referrals and treatment.
Identify, Teach and Treat (IT2): Automating Clinical Decision Pathways for the Care of Women (U18) (https://reporter.nih.gov/project-details/10377834)
PIs: Kimberly Sue Kenton; Steven Persell; Organization: Northwestern University at Chicago; Schools of Medicine, Internal Medicine; This project’s multi-level implementation strategy aims to improve care for urinary incontinence for women in primary care through systematic and equitable screening, supporting patient-centered decision making for selecting treatment options, and accelerating the uptake of evidence-based nonsurgical treatment modalities. This project will take place in the largest health system in Illinois, with 65 primary care practices and 327 primary care physicians.
Bridging Community-based Continence Promotion and Primary Care (U18) (https://reporter.nih.gov/project-details/10377670)
PIs: Heidi Wendell Brown; Kathryn E Flynn; Joan Marie Neuner; Organization: University of Wisconsin—Madison; School of Medicine; Aims to increase the proportion of patients who are screened and ofered treatment for urinary incontinence (UI) in 50 primary care practices. The intervention, called UI Assist, includes screening, education, and evidence-based treatment. The research team will also compare implementation of UI Assist alone or in combination with partnership building to help practices overcome barriers to intervention implementation.

#### Initiatives and Resources

AHRQ has initiatives as well as resources related to Practice and Quality Improvement in primary care that were ongoing or new in 2021 and 2022. These include AHRQ’s EvidenceNOW initiatives, and materials related to practice facilitation and practice-based research networks (PBRNs). Additional information and links are included below.

Evidence Now logo

AHRQ’s EvidenceNOW model (https://www.ahrq.gov/evidencenow/model/index.html) serves as a “blueprint for delivering external support to primary care practices to healthcare quality and implement new evidence into care delivery.”^(11)^ The model is defined by the following core services delivered as part of the external support to primary care practices:

- Practice facilitation and coaching
- Health information technology support
- Shared learning collaboratives
- Expert consultation
- Data feedback and benchmarking

EvidenceNOW Tools for Change (https://www.ahrq.gov/evidencenow/tools/index.html) is a searchable database of tools and resources that primary care practices and those who support practices can use to implement quality improvement, organized based on a key driver diagram. The curated collection of resources included in Tools for Change contains over 100 tools and continues to be developed over time. Newly developed tools from 2021 and 2022 include:

- Integrating Cardiovascular Disease Risk Calculators into Primary Care (https://www.ahrq.gov/sites/default/files/wysiwyg/evidencenow/heart-health/cvd-risk-calculator.pdf)
- Recruitment and Retention of Primary Care Practices in Quality Improvement Initiatives: A Toolkit (https://www.ahrq.gov/sites/default/files/wysiwyg/evidencenow/tools-and-materials/recruitment-and-retention-toolkit.pdf)

The EvidenceNOW model was developed based on EvidenceNOW: Advancing Heart Health (https://www.ahrq.gov/evidencenow/projects/heart-health/index.html) – the first EvidenceNOW initiative which launched in 2015. While the 6 grants for this initiative ended in 2018, AHRQ has continued to develop materials to share what was learned. These recent materials include the following:

- Videos Tell the Story of EvidenceNOW: Advancing Heart Health (https://www.ahrq.gov/evidencenow/projects/heart-health/research-results/videos/index.html)
- EvidenceNOW: A Model for Heart Health and Beyond (https://www.ahrq.gov/sites/default/files/wysiwyg/evidencenow/heart-health/evidencenow-story.pdf)
- Bridging Research & Practice in Primary Care: Fact Sheet (https://www.ahrq.gov/sites/default/files/wysiwyg/evidencenow/heart-health/evidencenow-factsheet.pdf)

Building on the success of EvidenceNOW: Advancing Heart Health, AHRQ has gone on to fund three additional initiatives based on use of the EvidenceNOW model to provide external support to implement evidence into primary care. These three initiatives are described below. :

- EvidenceNOW: Building State Capacity (https://www.ahrq.gov/evidencenow/projects/state/index.html). The aim of this initiative is to build state capacity and infrastructure to support primary care practices with implementing evidence-based heart health interventions, and decrease health disparities, in States with a high prevalence of preventable cardiovascular events. This initiative includes four grantees in Alabama, Ohio, Michigan, and Tennessee (described in greater detail in the grants section above), and a technical assistance and evaluation contract (led by Abt Global).^(12)^
- EvidenceNOW: Managing Unhealthy Alcohol Use (https://www.ahrq.gov/evidencenow/projects/alcohol/index.html). This initiative aims to increase the implementation of screening for unhealthy alcohol use in primary care, followed by a brief intervention and referral to treatment as indicated.^(13)^ AHRQ funded six grants in Michigan, Virginia, North Carolina, Colorado, Oregon, and Illinois and Wisconsin (described in greater detail in the grants section above), as well as a Resource Center and Evaluation contract led by NORC at the University of Chicago.
- EvidenceNOW: Managing Urinary Incontinence (https://www.ahrq.gov/evidencenow/projects/urinary/index.html). This initiative, launched in 2022, supports primary care practices to implement evidence-based, nonsurgical treatments for urinary incontinence in women, including behavioral approaches, medications, and neuromodulation. The five grantees include University of Alabama at Birmingham; University of Wisconsin, Madison; University of California, San Diego; Northwestern University; and University Hospitals of Cleveland (described in greater detail in the grants section above). AHRQ also funded a contract to support a learning community for the grantees and evaluate the program’s impact, led by the RAND Corporation.^(14)^ Materials developed for this project in 2021 and 2022 include:
  - Managing Urinary Incontinence for Women in Primary Care: Environmental Scan (Base Year) (https://www.ahrq.gov/sites/default/files/wysiwyg/evidencenow/projects/urinary/managing-ui-envscan-report.pdf)
  - Webinar on AHRQ’s Initiative to Improve Management of Urinary Incontinence in Primary Care (https://www.youtube.com/watch?v=mWH_dkSklG0)

Practice Facilitation

Practice facilitation (https://www.ahrq.gov/evidencenow/practice-facilitation/index.html) is an approach to supporting quality improvement in primary care practices with individualized trained practice coaches (known as practice facilitators).^(15)^ In addition to previously developed resources (https://archive.ahrq.gov/ncepcr/tools/transform-qi/deliver-facilitation.html) to describe practice facilitation, train practice facilitators, and advise program development and deployment, AHRQ developed the following materials in 2021 and 2022:

■ AHRQ Practice Facilitation Training Modules (https://www.ahrq.gov/ncepcr/tools/transform-qi/deliver-facilitation/modules/index.html). These 20-30 minute interactive modules – based on AHRQ’s Primary Care Practice Facilitation Curriculum (https://www.ahrq.gov/ncepcr/tools/transform-qi/deliver-facilitation/curriculum/index.html) – teach practice facilitators the skills they need to be effective. The modules are available to upload to learning management systems to track their completion by trainees by sending an email request to: pftraining@ahrq.hhs.gov.
■ Obtaining and Using Data in Practice: A Handbook for Health IT Advisors and Practice Facilitators (https://www.ahrq.gov/sites/default/files/wysiwyg/ncepcr/tools/healthit-advisor-handbook.pdf). This handbook provides detailed guidance for people who support primary care practices with their health information technology (IT) needs related to quality improvement and practice transformation efforts.^(16)^
■ This infographic (https://www.ahrq.gov/sites/default/files/wysiwyg/evidencenow/practice-facilitators-effectiveness-infographic.pdf) provides an overview of the most effective strategies used by practice facilitators based on findings from the EvidenceNOW: Advancing Heart Health initiative.

AHRQ also provides a grant to fund the annual International Conference on Practice Facilitation (ICPF) hosted by the North American Primary Care Research Group (NAPCRG), as described in grants above.

Practice-based Research Networks (https://www.ahrq.gov/ncepcr/communities/pbrn/index.html) (PBRNs)

AHRQ defines a PBRN as “a group of ambulatory practices devoted principally to the primary care of patients, and affiliated in their mission to investigate questions related to community-based practice and to improve the quality of primary care.”^(17)^ PBRNs serve as a “natural laboratory” for conducting dissemination and implementation (D&I) research in a real-world practice setting.

After previously funding the development of PBRNs and providing support through a national resource center and an electronic research repository, AHRQ’s direct support to PBRNs has decreased in recent years. However, several of the AHRQ funded grants in 2021 and 2022 are conducted by or with PBRNS. In addition, AHRQ provides a grant to fund the PBRN Conference hosted by NAPCRG, as described in grants above. In the future, AHRQ plans to reengage and more actively support PBRNs.

### Healthcare Systems and Infrastructure

Part of AHRQ’s mission from the public health service act that instituted the agency is,

“… conducting and supporting (1) research that develops and presents scientific evidence regarding all aspects of health care, including… the ways in which health care services are organized, delivered, and financed and the interaction and impact of these factors on the quality of patient care.”^(3)^

This aim includes an explicit focus on how the health system is organized and structured. Healthcare financing and payment reform continue to be opportunities to improve access to care and healthcare quality. Fee for service models limit the ability for healthcare systems to pay for services that optimize care, such as care coordination and improvements in healthcare access.^(18)^ Healthcare system redesign, including models like the Chronic Care Model and the Patient-Centered Medical Home, have the opportunity to improve both the quality and eficiency of care.^(19)^ One way to improve care is to improve coordination between settings and systems of care, such as between primary care and specialty care and during transitions between settings of care. The primary goal for care coordination is to incorporate the needs and preferences of patients and their caregivers into the delivery of high-quality and high-value health care.^(20)^

This section includes a summary of AHRQ’s primary care grants, initiatives, and resources with a main focus on healthcare systems and infrastructure, including issues of payment.

[image] Grants with a focus on health equity are indicated with this icon

#### Grants

There were 24 AHRQ primary care grants that were actively funded during FYs 2021 and 2022 that focused mainly on healthcare systems or infrastructure, including payment. This included 12 R01s (Research Projects), 5 R18s (Research Demonstration and Dissemination Projects), 3 K08s (Mentored Clinical Scientist Development Award), 1 R36 (Dissertation Award), 1 R03 (Small Research Grant), 1 K18 (Research Career Enhancement Award for Established Investigators), and 1 U18 (Research Demonstration / Cooperative Agreement). An additional 11 primary care grants had some focus on healthcare systems or infrastructure and are described in other sections of this report, including Practice and Quality Improvement (4), Health Equity (3), Digital Healthcare (2), Public Health and Community Integration (1), and COVID-19 (1).

Below are tables, organized by subtopic, which include short summaries of the 24 studies focused mainly on healthcare systems or infrastructure. The four subtopics include healthcare financing and payment reform, primary care redesign, care coordination across settings, and building center and laboratory infrastructure to improve patient safety.

##### Healthcare Financing and Payment Reform

Six studies focus on healthcare financing and payment reform, as described in the following table.

[image] Medicaid Payment Policy and Access to Care for Dual Eligible Beneficiaries (R01) (https://reporter.nih.gov/project-details/9993514)
PI: Vicki Fung; Organization: Massachusetts General Hospital; Examines the impact of temporary Afordable Care Act increases in Medicaid payment rates for primary care providers in 2013 and 2014 on care quality, clinical events, and medical spending.; Read Research Profile #4
The Efects of Expanding Medicare Prevention Coverage on Colorectal and Breast Cancer Burden: A Mixed Methods Study (R36) (https://reporter.nih.gov/project-details/9986240)
PI: Mika K. Hamer; Organization: University of Colorado Denver; School of Public Health, Public Health & Preventive Medicine; Investigates the impact of the Medicare Annual Wellness Visit on breast and colorectal cancer outcomes. The Medicare Annual Wellness Visit is an annual primary care check-up with no cost-sharing for the patient.
[image] Reproductive Care in the Safety Net: Women’s Health Afer Afordable Care Act Implementation (EVERYWOMAN) (R01) (https://reporter.nih.gov/project-details/10148802)
PI: Erika K. Barth Cottrell; Organization: OCHIN, Inc.; Studies the impact of Afordable Care Act and Medicaid expansion on reproductive healthcare provided in community health centers, including examining what individual-, clinic-, and State-level factors are associated with improved reproductive health provision.; Read Research Profile #5
Synergies and Sequencing in Delivery and Payment Reform: Understanding What Works (R01) (https://reporter.nih.gov/project-details/10233948)
PI: Julia Rose Adler-Milstein; Organization: University of California, San Francisco; School of Medicine, Internal Medicine; Examines the participation by primary care organizations in payment reform models including the Medicare and Medicaid EHR incentive program “Meaningful Use,” patient centered medical homes (PCMH), and Accountable Care Organizations. The study team looks at the combined impact of participation in these models on the quality and value of the primary care provided.; Read Research Profile #6
Primary Care Involvement in End Stage Renal Disease Seamless Care Organizations (ESCOs) and the Quality and Costs of Care for Patients on Chronic Dialysis (R01) (https://reporter.nih.gov/project-details/10328556)
PIs: Vahakn B. Shahinian; Richard A. Hirth; John Malcolm Hollingsworth; Organization: University of Michigan at Ann Arbor; School of Medicine, Internal Medicine; Studies End Stage Renal Disease (ESRD) Seamless Care Organizations (ESCO), including whether ESCOs impact the frequency and quality of primary care provider and nephrologist interactions, involvement of PCPs on financial and clinical outcomes, and outcomes for patients in ESCO versus other payment models including Accountable Care Organizations and Medicare Shared Savings Plans.
Analysis of a Tiered Clinic Cost-sharing Health Insurance Benefit Design (R01) (https://reporter.nih.gov/project-details/10367574)
PI: Bryan E. Dowd; Organization: University of Minnesota; Biomedical Engineering / College of Engineering; Evaluates a long running tiered cost-sharing system where Minnesota State employees select a primary care clinic that is responsible for coordinating their care, including referrals to specialists, hospital care, and use of pharmaceuticals. Clinics are assessed on their risk-adjusted total cost of care and cost savings are shared with patients, incentivizing them to select care coordination through lower-cost clinics. This study specifically explores clinical leaders’ perceptions of the system, how they have responded to being included in the system, and the barriers they face to practicing more eficiently.

##### Primary Care Redesign

Five studies focus on primary care redesign interventions, including examining the impact of new models for primary care including Patient Centered Medical Home (PCMH) and Centers for Medicare and Medicaid Services’ (CMS’) Comprehensive Primary Care Plus (CPC+).

[image] Efect of the Patient-Centered Medical Home on Geographic and Racial Disparities in Health Care Access (R03) (https://reporter.nih.gov/project-details/10004638)
PI: Nathaniel Bell; Organization: University of South Carolina at Columbia; School of Nursing Examines proximity and utilization of patient-centered medical homes (PCMH) for pediatric Medicaid patients in South Carolina to better understand the association between where a patient lives and their use of a PCMH instead of a hospital for care.; Read Research Profile #7
Social Networks in Medical Homes and Impact on Patient Care and Outcomes (R01) (https://reporter.nih.gov/project-details/10326793)
PI: Lusine Poghosyan; Organization: Columbia University Health Sciences; School of Nursing; Uses social network analysis to examine how staf connections afect team performance and patient outcomes within primary care practices using the Patient Centered Medical Home model.
[image] Examining Payment and Delivery Model Impacts on Health Equity Using Novel Quasi-Experimental Causal Inference Methods (R01) (https://reporter.nih.gov/project-details/10499748)
PI: Laura Hatfield; Organization: Harvard Medical School; School of Medicine; Tests the impact of the Comprehensive Primary Care Plus (CPC+) model on health outcomes for Black Medicare beneficiaries, including an examination of the variation in responses to CPC+ within subgroups by gender, disability, and Medicaid eligibility status.
Impact of a Team-Based Approach to Primary Care: A Natural Experiment in Primary Care Redesign (K08) (https://reporter.nih.gov/project-details/9980341)
PI: Anita Diana Misra-Hebert; Organization: Cleveland Clinic Foundation; Implements and tests the team-based care medical assistant (MA) model in primary care compared to usual care. In the team-based care MA model, two MAs are paired with each medical provider to support documentation and other administrative work.
Costs and Quality of Primary Care Services: Implications for Community Health Centers (R01) (https://reporter.nih.gov/project-details/10326795)
PI: Avi Dor; Organization: George Washington University; School of Public Health, Public Health & Preventive Medicine; Conducts an economic analysis of community health centers, including examining whether service expansion and integrating primary care visits with specialty visits leads to increased cost-savings and improved care quality.

##### Care Coordination Across Settings

Seven studies focus on care coordination across settings, as described in the following table.

Comprehensive Pediatric Hypertension Diagnosis and Management (R01) (https://reporter.nih.gov/project-details/9984368)
PI: Michael L. Rinke; Organization: Albert Einstein College of Medicine; Engages pediatric primary care practices to test diferent models of subspecialist involvement in pediatric hypertension diagnosis and management.
[image] Reducing Major Amputations for Rural Patients with Diabetic Foot Ulcers: The Who’s and How’s of Integrated Care (K08) (https://reporter.nih.gov/project-details/10202729)
PI: Meghan Brennan; Organization: University of Wisconsin—Madison; School of Medicine, Internal Medicine; Develops and pilots an integrated care algorithm to reduce amputation from diabetic foot ulcers for rural healthcare systems through interventions that rural patients receive in an ambulatory setting.
Implementing Personalized Cross-Sector Transitional Care Management to Promote Care Continuity, Reduce Low Value Utilization, and Reduce the Burden of Treatment for High-Need, High-Cost Patients (R01) (https://reporter.nih.gov/project-details/10376219)
PI: Sharon Hewnerh; Organization: State University of New York at Bufalo; School of Nursing; Tests a personalized, cross-sector, transitional care management model in primary care and behavioral health settings to improve care coordination across settings using a health information exchange infrastructure.
Tele-Recovery: Engaging Stakeholders to Adapt and Pilot Test a Scalable Transitional Rehabilitation Intervention for Older, Rural ICU Survivors (K08) (https://reporter.nih.gov/project-details/10254248)
PI: Leslie Page Scheunemann; Organization: University of Pittsburgh at Pittsburgh; School of Medicine, Pediatrics; Tests a transitional care model, TeleRecovery, where a nurse practitioner and occupational therapist deliver telehealth-based rehabilitation services for older adults and their caregivers in rural areas afer a transfer from the intensive care unit to home. The TeleRecovery teams work with home health providers to implement the patients’ care plans until they are well enough to be managed in primary care.
Integrating Pharmacists into an Automated Discharge Process to Promote Comprehensive Medication Management (R18) (https://reporter.nih.gov/project-details/10435446)
PI: Joel F. Farley; Organization: University of Minnesota; Examines pharmacist-provided comprehensive medication management to coordinate care for high-need/high-cost patients when they transition between the hospital and primary care settings. In this program, a health information exchange’s automated electronic alert system notifies primary care sites when patients need pharmacist-provided comprehensive medication management afer a hospital visit.
Improving How Older Adults at Risk for Cardiovascular Outcomes Are Selected for Care Coordination (K18) (https://reporter.nih.gov/search/WrQ8FP8YQE2LKBt0i7IOGQ/project-details/10572544)
PI: Lisa M. Kern; Organization: Weill Medical College of Cornell University; School of Medicine, Internal Medicine; Examines diferent models for assigning care coordinators to Medicare beneficiaries afer hospital discharge to improve the coordination of their care.
Closed Loop Diagnostics: AHRQ R18 Patient Safety Learning Laboratories (R18) (https://reporter.nih.gov/project-details/10252794)
PIs: Russell Scott Phillips; James C. Benneyan; Gordon David Schif; Organization: Harvard Medical School; Uses systems engineering methods to reduce diagnostic errors by creating “closed loop systems” or systems that ensure diagnostic tests and referrals are completed, results are conveyed to patients and primary care providers, and patients inform primary care providers about changes in symptoms that could alter a diagnosis. This study designs, develops, tests, and refines this “closed loop system” for diagnostic tests and referrals.

##### Building Center and Laboratory Infrastructure to Improve Patient Safety

Three studies focus on building centers and laboratory infrastructure to improve patient safety.

Re-engineering Patient and Family Communication to Improve Diagnostic Safety Resilience (R18) (https://reporter.nih.gov/search/p5h9-RQMk0O-7w2fVGYZVA/project-details/10641384)
PIs: Kathleen Elizabeth Walsh; Christopher Paul Landrigan; Organization: Boston Children’s Hospital; Develops a Diagnostic Center of Excellence focused on improving clinician-patient/family communication in pediatric outpatient settings.
[image] Safety II Together: Coupling Teaming Science with Patient Engagement and Health Information Transparency to Coproduce Diagnostic Excellence (R18) (https://reporter.nih.gov/search/T7YgQ3_as0u6eLYjq8RIJA/project-details/10642466)
PI: Sigall Bell; Organization: University of Texas Health Science Center Houston; Internal Medicine; Develops a Diagnostic Center of Excellence that uses teaming science and patient engagement to bring patients and healthcare providers together to reduce diagnostic errors and improve safety in ambulatory care.
PROMIS Learning Lab: Partnership in Resilience for Medication Safety (R18) (https://reporter.nih.gov/project-details/10251914)
PI: Yan Xiao; Organization: University of Texas Arlington; School of Nursing; Creates the Partnership in Resilience for Medication Safety Learning Lab (PROMIS Lab) which promotes patient safety in primary care. The PROMIS Lab is intended to develop and test strategies to reduce medication-related harms in older adults.

##### Other Healthcare Systems and Infrastructure Topics

The final three studies each focus on a unique topic.

Consumer Assessment of Healthcare Providers and Systems V (CAHPS V) (U18) (https://reporter.nih.gov/project-details/10252801)
PI: Ronald Dale Hays; Organization: RAND Corporation; Expands the Consumer Assessment of Healthcare Providers and Systems (CAHPS) survey to include modules related to patient experience, shared decision-making, care coordination, patient engagement, and patient safety. Among other activities, this study looks at how primary care practices use the CG-CAHPS survey and patient-centered medical home items during PCMH transformation, and assesses how pay- for-performance impacts CAHPS survey responses about the care provided by primary and specialty care safety net providers.
Novel, High-Impact Studies Evaluating Health System and Healthcare Professional Responsiveness to COVID-19 (R01) (https://reporter.nih.gov/project-details/10318222)
PI: Rebecca Sarah Etz; Organization: Virginia Commonwealth University; Family Medicine; Examines the impact that COVID-19 has had on digital healthcare expansion in primary care, using a set of surveys developed and implemented during the public health emergency.
Physician Organization and the Use, Cost and Outcomes of Care (R01) (https://reporter.nih.gov/search/_da2vy_Xv0-OrUfhaMCe4w/project-details/9831169)
PI: Laurence C. Baker; Organization: Stanford University; School of Medicine, Internal Medicine; Examines the impact of the growing role of physician organizations on healthcare cost, use, and outcomes. A physician organization is a business entity where physicians form a group practice to support an afordable care organization or managed care organization.^(21)^ The study examines whether physician organization size or practice composition (single versus multispecialty groups) afects cost, use, and health outcomes.

#### Initiatives and Resources

AHRQ invests in data collection activities that can support research in healthcare systems and infrastructure that have implications for primary care. The data resources are described below with links to additional information or to the specific material.

MEPS logo

The Medical Expenditure Panel Survey (https://meps.ahrq.gov/mepsweb/) (MEPS) is the largest national data source for measuring how people use and pay for medical care in the U.S. It includes a set of surveys of individuals and households, their medical providers, and employers across the U.S. While MEPS includes information about a broad set of medical services beyond primary care, it may be a helpful source of data for primary care researchers.

As described on the MEPS webpage: “MEPS currently has two major components: the Household Component (https://meps.ahrq.gov/mepsweb/survey_comp/household.jsp) and the Insurance/Employer Component (https://meps.ahrq.gov/mepsweb/survey_comp/Insurance.jsp). The Household Component provides data from individual households and their members, which is supplemented by data from their medical providers. The Insurance Component is a separate survey of employers that provides data on employer-based health insurance.”^(22)^

### Digital Healthcare

Investment and expansion of digital healthcare, which includes mobile health (mHealth) and electronic health (eHealth), health information technology, wearable devices, and providing patient care and support through telemedicine^,(23)^ has grown significantly in recent years. The COVID-19 public health emergency accelerated this growth, particularly for telemedicine and related technologies. Integrating digital healthcare technology into primary care has the promise of increasing access to services, enhancing care coordination across healthcare settings, supporting clinical decision-making, and improving patient safety and health outcomes. However, research indicates that digital healthcare approaches can exacerbate existing disparities in healthcare, requiring dedicated interventions that center health equity in improved design, implementation, and dissemination of digital healthcare tools to those who have the greatest need.^(24)^ Ongoing research continues to explore new avenues for expanding digital healthcare technology in ways that improve equitable access to high-quality health care.

AHRQ’s Division of Digital Healthcare Research (https://digital.ahrq.gov/) produces and disseminates evidence on how digital healthcare can improve the quality, safety, and efectiveness of healthcare while also improving patient experiences. However, many AHRQ grants that have a focus on digital healthcare intersect with other agency priorities. This section of the report includes a summary of AHRQ’s primary care grants, initiatives, and resources with a main focus on digital healthcare.

[image] Grants with a focus on health equity are indicated with this icon

#### Grants

Twenty-two AHRQ primary care grants actively funded during FYs 2021 and 2022 were mainly focused on digital healthcare. This included 12 R18s (Research Demonstration and Dissemination Projects), 5 R01s (Research Projects), 3 R21s (Exploratory/ Developmental Grants), 1 U18 (Research Demonstration / Cooperative Agreement), and 1 K08 (Clinical Investigator Award). In addition to these 22 grants, another 38 primary care grants had some focus on digital healthcare and are described in other sections of this report, including Practice and Quality Improvement (15), Person-Centered Care (7), Healthcare Systems and Infrastructure (5), Behavioral Health and Substance Use Disorders (5), COVID-19 (2), Health Equity (1), Primary Care Workforce (1), and Public Health and Community Integration (1).

Below are tables, organized by five subtopics, which include short summaries of each of the 22 primary care grants focused mainly on digital healthcare. Subtopics include clinical decision support tools, other EHR tools, mobile health and electronic health approaches, telemedicine or telehealth, and diagnostic centers of excellence.

##### Clinical Decision Support Tools

Out of eight grants investigating EHR tools, five focus specifically on clinical decision support (CDS) tools to help clinicians reduce errors and improve the consistency of diagnoses and care recommendations. CDS describes a range of tools that can be used to help support decision-making in the clinical workflow. CDS tools include “computerized alerts and reminders to care providers and patients; clinical guidelines; condition-specific order sets; focused patient data reports and summaries; documentation templates; diagnostic support, and contextually relevant reference information, among other tools.”^(25)^ All of AHRQ primary care grants with a focus on CDS throughout this report are included in Appendix C: Clinical Decision Support.

Engaging Patients to Enable Interoperable Lung Cancer Decision Support at Scale (R18) (https://reporter.nih.gov/project-details/10410792)
PI: Kensaku Kawamoto; Organization: University of Utah; School of Medicine; Expands an existing CDS program (Decision Precision+) designed to analyze EHR data to prompt doctors to discuss lung cancer screening with eligible patients with individually tailored information on the benefits and harms of screening. For this grant, the research team will adapt Decision Precision+ to integrate with a patient portal (MyLungHealth) that patients use directly to learn about lung cancer screening. The research team will test how healthcare systems implement MyLungHealth in primary care practices and examine the additional benefit of MyLungHealth for practices that already use Decision Precision+.
Averting Diagnostic Error Through Improved Recognition of Child Abuse (K08) (https://reporter.nih.gov/search/wV0BDUjTZkKsylWR0w4EyA/project-details/10591944)
PI: Irit R. Rasooly; Organization: Children’s Hospital of Philadelphia; Independent Hospital; Uses EHR data- and systems-analysis to develop CDS strategies that can identify and help diagnose child abuse in primary care settings. The research team is using EHR data to detect and validate markers of physical abuse to help identify children experiencing abuse; using EHR simulations to identify abuse-related diagnostic errors; and working to develop feasible, acceptable, and appropriate CDS strategies for improved child abuse detection and diagnosis.
Clinical Decision Support for Disseminating and Implementing Patient-Centered Outcomes Research (R18) (https://reporter.nih.gov/search/GGcT5W-uSEmN7xIEqIN3mQ/project-details/10553545)
PI: Ronilda Lacson; Organization: Brigham and Women’s Hospital; Independent Hospital; Aims to develop and validate CDS-consumable knowledge artifacts based on clinical evidence for imaging that can be widely adopted. In previous work, a multi-disciplinary team of clinicians and medical informaticists developed and graded artifacts to represent clinical evidence and made them publicly available. Assesses the technical capability of standardized EHR syntax and formats (e.g., FHIR, CQL, and SNOMED CT) to use the knowledge artifacts for imaging CDS. Specifically, the team will look at CDS for using MRI to diagnose a second incidence of breast cancer, using CT scan for pulmonary embolism, and for physician education about the risk for pulmonary embolism. Results will help inform clinical decision making for diagnostic imaging in primary care.
Shareable, Interoperable Clinical Decision Support for Older Adults: Advancing Fall Assessment and Prevention Patient-Centered Outcomes Research Findings into Diverse Primary Care Practices (ASPIRE) (U18) (https://reporter.nih.gov/project-details/10224618)
PIs: Patricia C. Dykes; Robert J. Lucero; Organization: Brigham and Women’s Hospital; Aims to develop a shareable, standards-based fall prevention sofware to improve the implementation of a clinical decision support program into primary care settings using Fall Care Managers to promote fall prevention decision-making.
Adaptation and Pilot Implementation of a Validated, Electronic Real Time Clinical Decision Support Tool for Care of Pneumonia Patients in 12 Utah Urgent Care Centers (R18) (https://reporter.nih.gov/project-details/10268162)
PI: Nathan C. Dean; Organization: IHC Health Services Inc.; Non-Profit; Adapts an existing CDS tool containing guidelines for pneumonia (“ePNa”) to urgent care centers. The research team is identifying barriers and facilitators to implementation and uptake of the ePNa tool, and testing it within urgent care centers by examining outcomes related to patient safety, antibiotic prescribing, and diagnoses without chest imaging. While this study is not conducted in primary care practices, it has potential to be implemented in primary care practices, as acute respiratory complaints are commonly seen in primary care.

##### Other EHR Tools

Four grants focus on EHR tools other than CDS.

Understanding CancelRx: Impact on Clinical Workflows, Medication Safety Risks, and Patient Outcomes (R21) (https://reporter.nih.gov/search/Kec3JKtuEUOyqovjVI1ANQ/project-details/10018011)
PI: Samantha Pitts; Organization: Johns Hopkins University; School of Medicine; Genetics; Conducts formative research on the development and optimization of CancelRx, an EHR functionality that sends electronic prescription cancellations from the EHR to pharmacies, to help reduce adverse drug events in ambulatory care settings.
Care System Analytics to Support Primary Care Patients with Complex Medical and Social Needs (R18) (https://reporter.nih.gov/project-details/10259671)
PI: Richard W. Grant; Organization: Kaiser Foundation Research Institute; Research Institute; Develops and tests an EHR-based dashboard to help clinical teams ensure patients with multiple chronic conditions and socially determined barriers to care receive high-quality primary care.; Read Emerging Research Spotlight #1
Prescription Drug Monitoring Program Integration in the Electronic Health Record (R21) (https://reporter.nih.gov/project-details/10374016)
PI: Daniel M. Hartung; Organization: Oregon State University; School of Pharmacy; Other Health Professions; Evaluates how integrating Oregon’s electronic registry of controlled-substance prescription dispensing data (prescription drug monitoring program) into the EHR of primary care clinics impacts provider use of registry data and prescribing behavior.
A Turn-Key EHR Simulation Program to Reduce Diagnostic Error in Ambulatory Care (R18) (https://reporter.nih.gov/project-details/10470775)
PIs: Jeffery A. Gold; Raj M. Ratwani; Organization: Oregon Health & Science University; Domestic Higher Education; Develops a library of validated EHR-based simulations to improve diagnostic safety in ambulatory care. The research team is using a combination of administrative and claims data to identify diagnoses at risk for diagnostic error in ambulatory care settings and the EHR use errors associated with those errors. The researchers will use this data to develop simulations for five ambulatory care settings, including primary care, and validate the use of the simulation activities as a training tool to change EHR use patterns and reduce diagnostic errors.; Read Emerging Research Spotlight #2

##### Mobile Health and Electronic Health

Eight grants focus on mHealth or eHealth interventions.

[image] Adapting, Scaling, and Spreading an Algorithmic Asthma Mobile Intervention to Promote Patient-Reported Outcomes Within Primary Care Settings (R18) (https://reporter.nih.gov/project-details/9926777)
PI: Sunit Jariwala; Organization: Albert Einstein College of Medicine; Domestic Higher Education; Develops and evaluates an app for asthma control in adults and tests its implementation and scaling within primary care settings.
Integrating Patient-Reported Outcomes into Routine Primary Care: Monitoring Asthma Between Visits (R18) (https://reporter.nih.gov/project-details/9984366)
PI: Robert Samuel Rudin; Organization: RAND Corporation; Research Institute; Refines an app for reporting asthma symptoms for use in a primary care setting, implements it in four primary care clinics, and evaluates the efect of patient use on quality of life and healthcare utilization.
Impact and Sustainability of a Digitally-Based Diabetes Prevention Program (R01) (https://reporter.nih.gov/project-details/10454223)
PI: Yoshimi Fukuoka; Organization: University of California, San Francisco; School of Nursing; Other Health Professions; This randomized controlled trial assesses the efectiveness and sustainability of a digitally-based diabetes prevention program for reducing body weight and HbA1c in adults with prediabetes and obesity. The findings from this study have clear implications for primary care, where diabetes prevention is a common part of care.
Feasibility Study of a Mobile Digital Personal Health Record for Family-Centered Care Coordination for Children and Youth with Special Healthcare Needs (R21) (https://reporter.nih.gov/project-details/10352504)
PI: David Y. Ming; Organization: Duke University; School of Medicine; Pediatrics; Develops an app for families of children and youth with special healthcare needs to manage digital personal health records that span healthcare and EHR systems. The study will explore app adoption, barriers and facilitators, and outcomes among families of children with special healthcare needs in a pediatric primary care clinic.
Improving Medication Safety for Medically Complex Children with MHealth Across Caregiving Networks (R18) (https://reporter.nih.gov/project-details/10411594)
PIs: Ryan J. Coller; Nicole E. Werner; Organization: University of Wisconsin—Madison; School of Medicine; Pediatrics; Develops an app (MedS@HOME) to improve medication safety for children with medical complexity. The app supports standardized medication management across the caregiving network to increase administration accuracy and reduce medication-related adverse events.; Learn more about this study in a recent NCEPCR webinar: Innovative Use of Technology for Primary Care Delivery (https://www.ahrq.gov/ncepcr/about/pcr-webinar-series/innovative-use.html).
Care Transitions App for Patients with Multiple Chronic Conditions (R01) (https://reporter.nih.gov/search/GEX3le-Wd0eb9AHku1X9WA/project-details/10365310)
PIs: Lipka Samal; Patricia C. Dykes; Organization: Brigham and Women’s Hospital; Independent Hospital; Develops and tests the efectiveness of an app to support care transitions between the hospital, home, and primary care clinic to reduce post-discharge adverse events. The app contains a digital post-discharge transitional care plan, modules for multiple chronic conditions, relevant lab values, education specific to the patient’s prescribed medications, and a functionality that allows patients to ask questions to support their recovery goals.
An Evaluation of the Spread and Scale of PatientToc from Primary Care to Community Pharmacy Practice for the Collection of Patient-Reported Outcomes (R18) (https://reporter.nih.gov/project-details/10107723)
PI: Margie E. Snyder; Organization: Purdue University; School of Pharmacy; Pharmacology; Implements a patient-reported outcomes app for patients using community pharmacies to improve medication adherence and ultimately patient health outcomes.; Read Emerging Research Spotlight #3
Using Smart Devices to Implement an Evidence-based eHealth System for Older Adults (R18) (https://reporter.nih.gov/project-details/10457324)
PIs: David H. Gustafson; Marie-Louise Mares; Organization: University of Wisconsin—Madison; Biomedical Engineering/College of Engineering; Engineering; Implements a smart-system (a smart speaker plus display) version of an existing Elder Tree intervention – a program that supports the self-management of health for older adults with multiple chronic conditions. This grant tests a smart-system version compared to the computer-based system on outcomes, including quality of life, hospital readmission, and medication adherence.

##### Telemedicine or Telehealth

Three grants with a primary focus on Digital Healthcare examine the use of telemedicine or telehealth, including providing direct medical care and services using video conferencing or phone calls. [A total of 13 AHRQ primary care grants had a focus on telehealth, including the three described here. A table with all 13 of these grants is included in Appendix C: Telehealth.]

Patient Choice of Telemedicine Encounters (R01) (https://reporter.nih.gov/project-details/10350592)
PI: Mary Reed; Organization: Kaiser Foundation Research Institute; Research Institute; Examines the broad-scale implementation of telemedicine for primary care encounters within a healthcare system prior to the COVID-19 pandemic to understand how telemedicine compares in quality, care processes, and patient outcomes to in-person care; and to understand which patient characteristics are most closely associated with telemedicine utilization.; Read Research Profile #8
Evaluating the Impact of Telemedicine on Ambulatory Care (R01) (https://reporter.nih.gov/search/09oyDXy6xkqhLL8qkccKuw/project-details/10438959)
PIs: Michael Patrick Thompson; Chandy Skaria Ellimootil; Organization: University of Michigan at Ann Arbor; School of Medicine; Surgery; Uses a national cohort of Medicare beneficiaries to understand the impact of ambulatory care telemedicine visits on hospital admissions for ambulatory care-sensitive conditions (such as congestive heart failure, diabetes, and hypertension), and on healthcare spending.
[image] A Clinical Trial to Validate an Automated Online Language Interpreting Tool with Hispanic Patients Who Have Limited English Proficiency (R01) (https://reporter.nih.gov/project-details/9984361)
PI: Peter M. Yellowless; Organization: University of California at Davis; School of Medicine; Psychiatry; Tests and validates an automated online interpretation tool to improve access to high-quality mental health services for people with limited English proficiency. In this intervention, a trained mental health interviewer-researcher interviews a patient in Spanish, the interview is translated and transcribed using the automated translation tool, and then a video with embedded transcribed subtitles is viewed by the psychiatrist. The research team is testing diagnostic accuracy, inter-rater reliability, patient satisfaction, and language and syntax accuracy.

##### Diagnostic Centers of Excellence

Two grants support the implementation of Diagnostic Centers of Excellence focused on using digital healthcare to reduce diagnostic errors and improve patient safety.

Diagnostic Safety Center for Advancing E-triggers and Rapid Feedback Implementation (DISCOVERI) (R18) (https://reporter.nih.gov/search/gRMr6wlJfkSnfbsWqufGcg/project-details/10641526)
PI: Hardeep Singh; Organization: Baylor College of Medicine; School of Medicine; Internal Medicine; Develops a center that supports the implementation of surveillance and feedback systems to improve diagnostic safety in healthcare organizations. The center will work to accelerate the uptake of electronic trigger (e-trigger) tools, which mine large sets of clinical and administrative data to identify signals for likely adverse events. E-trigger algorithms can eficiently identify patterns of care indicating missed or delayed diagnoses in primary care as well as other settings.
[image] DECODE: Diagnostic Excellence Center on Diagnostic Error (R18) (https://reporter.nih.gov/search/cvvPhLkw_kaVDiQh0jeeQA/project-details/10641651)
PIs: Ramin Khorasani; Ronilda Lacson; Organization: Brigham and Women’s Hospital; Independent Hospital; Develops a Diagnostic Center of Excellence to reduce failures in timely performance of clinically necessary diagnostic imaging exams and interpretation errors. The team will implement information technology-enabled functions and workflows to enhance a clinical dashboard with improved EHR-integration and monitoring and learning capabilities to help reduce diagnostic errors and health disparities. In addition, they will provide opportunities for peer learning to reduce interpretive errors and convene a team of clinicians to develop consensus recommendations for the management of lung, prostate, pancreatic and adrenal cancers and embed the recommendations into the EHR.

#### Initiatives and Resources

Below we share an important resource related to digital healthcare in primary care that AHRQ developed in 2021.

Integrating Patient-Generated Health Data into Electronic Health Records in Ambulatory Care Settings: A Practical Guide (https://digital.ahrq.gov/sites/default/files/docs/citation/pghd-practical-guide.pdf)

is designed to support ambulatory care settings in the design and implementation of patient-generated health data (PGHD) programs, with the goal of improving patient outcomes.

PGHD are “health-related data created, recorded, or gathered by or from parents (or family members or other caregivers) to help address a health concern.”^(26)^ PGHD includes data reported in patient surveys or tracked in remote monitoring devices (i.e., health apps or wearable devices).

The guide includes tools and resources that support the planning, implementation, evaluation, and scaling of PGHD into ambulatory care settings.

### Person-Centered Care

It is now recognized that high-quality primary care is “continuous, person-centered, relationship-based care.”^(27)^ Person-centered care builds on the earlier concept of patient-centered care – where patients and their families are partners in medical decision making, and care is personalized based on the patient’s unique needs, preferences, and values.^(28)^ Person-centered care goes one step further, by putting the focus on the individual in the full context of their community, family, and lived experience – rather than solely on their role as a patient receiving healthcare.

To broadly implement person-centered care, shifs are needed in the organization, financing, and delivery of care to support the provision of comprehensive, whole person care rather than disease focused care.^(2)^ Providing person-centered care also requires strong and ongoing partnerships between primary care, public health, and communities^(27)^ (see the section on Public Health and Community Integration as well). Engaging patients and families as partners in research is essential for helping to identify the research questions and health outcomes that are most relevant to them, and to redesign care to be responsive to the needs of those receiving the care.

This section of the report includes a summary of AHRQ’s grants and a resource with a main focus on person-centered care.

[image] Grants with a focus on health equity are indicated with this icon

#### Grants

There were 18 AHRQ primary care grants focused on person-centered care that were actively funded during FYs 2021 and 2022. This included eight R01s (Research Projects), four R18s (Research Demonstration and Dissemination Projects), two U18s (Research Demonstration / Cooperative Agreement), two R21s (Exploratory / Developmental Research Grants), one R03 (Small Research Grant), and one K01 (Research Career Program). There were an additional 18 grants with some focus on person-centered care, which are described in other sections of this report, including Digital Healthcare (5), Healthcare Systems and Infrastructure (4), Behavioral Health and Substance Abuse Disorders (4), Practice and Quality Improvement (3), Health Equity (1), and Public Health and Community Integration (1). Below are tables, organized by subtopics, which include short summaries of the 18 studies focused mainly on person-centered care. Subtopics include clinical decision supports for person-centered care, decision aids, measures of shared-decision making, improving decision-making processes, patient-facing EHR-integrated tools, programs to improve person-centeredness, and other person-centered approaches to improving health.

##### Clinical Decision Supports for Person-Centered Care

Three grants focus on developing clinical decision support tools to help providers engage in person-centered care.

Scaling Interoperable Clinical Decision Support for Patient-Centered Chronic Pain Care (R18) (https://reporter.nih.gov/project-details/10488223)
PIs: Christopher Albert Harle; George Ramzi Solloum; Organization: University of Florida; School of Medicine; Develops and tests a clinical decision support tool to help primary care clinicians work with their patients to choose a pain treatment approach that best balances the potential risks and benefits for the individual patient.; Read Emerging Research Spotlight #4
Clinical Decision Support for Collaborative Diet Goal Setting in Primary Care (R21) (https://reporter.nih.gov/project-details/10204973)
PI: Marissa Burgermaster; Organization: University of Texas at Austin; School of Medicine, Public Health, and Preventive Medicine; Refines an existing health information technology tool that provides clinicians with data-driven guidance for personalized and collaborative diet goal setting. The research team will pilot test the tool with primary care providers in federally qualified health centers, with the goal of implementing clinical workflows to serve patients experiencing health disparities.
Scalable Decision Support and Shared Decision Making for Lung Cancer Screening (R18) (https://reporter.nih.gov/project-details/10141232)
PI: Kensaku Kawamoto; Organization: University of Utah; School of Medicine; Adapts an existing tool, Decision Precision+, to analyze and synthesize relevant risk data and support shared decision-making related to lung cancer screening. This tool presents individually tailored information on the potential benefits and harms of screening, allowing patients and their primary care physicians to make informed and patient-centered decisions on whether to screen for lung cancer through low-dose computerized tomography testing.

##### Decision Aids

Two grants develop decision aids to support decision-making and promote person-centered care.

Patient Perspectives on Prescription Opioid Discontinuation: Understanding and Promoting Safe Transitions (R01) (https://reporter.nih.gov/project-details/10294765)
PI: Clarissa Wen-Ling Hsu; Organization: Kaiser Foundation Research Institute; Investigates the experiences of patients and providers who have discontinued opioids for long term opioid therapy (LTOT). It develops a patient decision aid to support patients when discontinuing LTOT and pilot tests the decision aid with patients.
Patient-Centered Diabetes Education as an Integral Part of an Electronic Clinic Note Using the SEE-Diabetes Modules (R21) (https://reporter.nih.gov/project-details/10448825)
PI: Min Soon Kim; Organization: University of Missouri—Columbia; School of Medicine; Develops an educational decision aid that enables older adults with diabetes to choose a diabetes self-management education and support strategy with the best potential to achieve clinical and health benefits for them. The project also refines and tests the decision aid for feasibility in primary care and diabetes specialty care settings, and for preliminary outcomes.

##### Measures of Shared-Decision Making

Two grants work to develop measures of shared decision-making (SDM).

SDMo – a Measure of the Occurrence of SDM in the Care of Patients with Chronic Conditions (R01) (https://reporter.nih.gov/search/Wor_oI9M6kmDsWYVsqUOTQ/project-details/10559906)
PI: Ian Hargraves; Organization: Mayo Clinic Rochester; Develops a measure of shared decision making (SDM) occurrence and estimates the measure’s reliability and validity. This new measure of SDM occurrence can help uncover how frequently SDM techniques are used in the care of patients with chronic conditions, and test associations between SDM and behavioral and physical health outcomes.
Development of a Shared Decision Making Support (SDM-S) Measure for Use with Team-based Care (R01) (https://reporter.nih.gov/project-details/10478048)
PIs: Jennifer M. Elston Lafata; Organization: University of North Carolina Chapel Hill; School of Pharmacy; Develops valid patient-reported shared decision-making support (SDM-S) measures that incorporates four distinct SDM phases: choice awareness, consideration of alternatives/preferences, choice-making, and choice implementation. The researchers will then test the measures in four cancer care contexts (lung cancer screening, colorectal cancer screening, rectal cancer treatment, and prostate cancer treatment) to evaluate performance and acceptability among primary care and oncology patients.

##### Improving Decision-Making Processes

Three grants implement interventions to improve decision-making processes.

Validation of a Framework for Shared Decision-Making in Pediatrics (R03) (https://reporter.nih.gov/project-details/10147613)
PI: Douglas J. Opel; Organization: Seattle Children’s Hospital; Defines a framework for implementing SDM in pediatrics. The framework includes four steps: medical reasonableness, benefit-burden, preference sensitivity, and calibration. This grant assesses the applicability of the pediatric SDM framework on a range of medical decisions and child ages through observations of clinical encounters and post-encounter interviews with clinicians, parents, and adolescent patients. The research team will also assess the face and content validity of the framework through focus groups.
Comparing Family Decision Making Engagement in Telehealth Versus In-person Primary Care for Children with Chronic Conditions (R01) (https://reporter.nih.gov/search/TF9cVcFICk-DCrHC-gprDA/project-details/10560396)
PI: Ellen A. Lipstein; Organization: Cincinnati Children’s Hospital Medical Center; Aims to compare the telehealth and in-person decision-making processes and outcomes in pediatric primary care for children with chronic conditions. This grant used a combination of family surveys, video recordings of healthcare visits, and qualitative interviews to understand experiences of decision-making during telehealth and in-person visits.; Learn more about this study in a recent NCEPCR webinar: Qualitative Methods Used in AHRQ Funded Primary Care Research (https://www.ahrq.gov/ncepcr/about/pcr-webinar-series/qualitative-methods.html).
[image] Integrating Costs into Shared Decision-Making for Heart Failure with Reduced Ejection Fraction (R01) (https://reporter.nih.gov/project-details/10413851)
PI: Neal Workman Dicket; Organization: Emory University; School of Medicine, Internal Medicine; Investigates strategies to improve communication and shared decision-making related to a costly but medically efective drug to treat chronic heart failure with reduced ejection fraction. The grant explores how frequently cost is addressed in patient-provider encounters, examines the impact of diferent ways of framing information about the drug and its cost, and tests an intervention focused on integrating patient-specific costs into clinical encounters.

##### Patient-Facing EHR-Integrated Tools

Three grants develop patient-facing, EHR-integrated tools to support patients reporting outcomes or completing screenings.

i-Matter: Investigating an mHealth Texting Tool for Embedding Patient-Reported Data into Diabetes Management (R01) (https://reporter.nih.gov/project-details/10431814)
PIs: Antoinette M. Schoenthaler; Devin M. Mann; Organization: New York University Grossman School of Medicine; School of Medicine, Internal Medicine; Evaluates the useability and eficacy of an innovative mobile health tool for managing diabetes care. The tool uses text-messaging to collect and share patient-reported outcomes and sends patients feedback and motivational messages based on the information they share. The platform also creates dynamic data visualizations of the patient’s data, which is integrated into the electronic health record, and can be reviewed by their primary care clinicians during and between visits.; Read Research Profile #9
Mobile Patient-Reported Outcomes for Value and Efectiveness (mPROVE) (U18) (https://reporter.nih.gov/project-details/10246841)
PI: Jane Jih; Organization: University of California, San Francisco; School of Medicine, Internal Medicine; Develops a mobile app for patient-reported outcomes and shared decision-making, integrates it with the EHR, and conducts a hybrid implementation-efectiveness trial to study its impact on quality of care and implementation outcomes among primary care patients.; Read Emerging Research Spotlight #5
Patient Outcomes Reporting for Timely Assessments of Life with Depression: PORTAL-Depression (U18) (https://reporter.nih.gov/project-details/9933039)
PI: Neda Laiteerapong; Organization: University of Chicago; School of Medicine, Internal Medicine; Implements the Computerized Adaptive Test for Mental Health (CAT-MH), a validated, adaptive test that measures depression symptoms through the patient portal and is integrated into the EHR. The study evaluates the efectiveness of conducting depression screening through the patient portal versus in-person collection during primary care visits. The researchers aim to assess whether using MyChart increases the number of uses of the MAT-HC screener by primary care patients, and whether use of the integrated MAT-HC screener in MyChart results in higher rates of remission in patients with major depressive disorder.

##### Programs to Improve Person-Centeredness

Three grants implement programs to improve person-centeredness.

[image] Ready and Healthy for Kindergarten: A Primary Care Innovation to Promote a 360-degree View of Child Health (R18) (https://reporter.nih.gov/project-details/10653505)
PI: Manuel E. Jimenez; Organization: RBHS-Robert Wood Johnson Medical School; Tests an online family wellness program that uses anticipatory guidance on health topics important to school readiness (for example, nutrition and physical activity) to introduce language and literacy skills to Latino dual language learners from families with a low income. The research team will first conduct a developmental evaluation to refine and optimize the program for implementation in primary care. They will then conduct a randomized control trial to test the efects of the program on child and parent outcomes, and a process evaluation to explore reach, implementation, and user experience.
Addressing Opioid Use Disorder in Older Adults Through Primary Care Innovation (OUD-PCI) (R18) (https://reporter.nih.gov/project-details/10246916)
PIs: Steven Allen Crawford; Alexandra Lee Jennings; Zsolt J. Nagykaldi; Organization: University of Oklahoma Health Sciences Center; Implements a multi-faceted person-centered and scalable chronic management program in primary care practices. The program was systematically tailored to older adults and those with functional disabilities or increased social risks with the goal of increasing functioning and decreasing pain and adverse events.
Enhanced Care Planning and Clinical-Community Linkages to Comprehensively Address the Basic Needs of Patients with Multiple Chronic Conditions (R01) (https://reporter.nih.gov/project-details/10335134)
PI: Alexander H. Krist; Organization: Virginia Commonwealth University; School of Medicine, Medicine; Implements and tests an enhanced care planning program to help patients manage multiple chronic conditions. The intervention includes the use of an enhanced care planning tool in primary care to screen patients for health behavior, mental health, and social needs. Working with a navigator, patients help prioritize their needs, create a care plan, and write a narrative to guide care; and then connects patients to needed resources in the community. The research team implemented a clinician-level randomized controlled trial to study how primary care clinicians participate in models for connecting patients to needed community services, and measures whether it improves their health outcomes.; Read Research Profile #10

##### Other Person-Centered Approaches to Improving Health

Two grants investigate other person-centered approaches to improving health.

[image] Helping gEnerations Identify Risks (Heirs) to Health (R01) (https://reporter.nih.gov/project-details/10141231)
PI: Heather Angier; Organization: Oregon Health & Science University; School of Medicine, Family Medicine; Identifies which parental factors (such their own health care receipt and burden of disease) are most strongly associated with children receiving recommended preventive health care (including recommended well-child visits and routine childhood vaccinations). The research team also explores how social determinants of health influence healthcare utilization for the whole family.; Read Research Profile #11
Prioritizing Quality Improvement for the Treatment of Psychiatric Disturbances Following Traumatic Brain Injury (K01) (https://reporter.nih.gov/project-details/9876255)
PI: Jennifer S. Albrecht; Organization: University of Maryland Baltimore; School of Medicine, Public Health & Preventive Medicine; Assesses treatment options for patients with traumatic brain injury (TBI) who are experiencing psychiatric disturbances such as depression, anxiety, and post-traumatic stress disorder. The grant examines barriers and facilitators to treatments across patient groups, quantifies disparities in treatment patterns associated with psychiatric disturbances following TBI, and develops a priority list of patient-selected strategies to overcome barriers to the receipt of treatment for psychiatric disturbances following TBI. This project has implications for the care of patients with TBI in a primary care setting.

#### Initiatives and Resources

AHRQ’s Consumer Assessment of Healthcare Providers and Systems (CAHPS^®^) surveys help to build an understanding of patients’ experience with healthcare as part of a larger overall efort to ensure that care is safe and centered on patients’ needs.^(29)^ There are several CAHPS^®^ surveys focused on diferent areas of care. The CAHPS^®^ Clinician & Group Survey, which was updated in 2021, is focused on primary and specialty care settings and is described below.

cahps logo

The CAHPS Clinician & Group Survey (https://www.ahrq.gov/cahps/surveys-guidance/cg/index.html), asks patients to report on their experiences with providers and staf in primary and specialty care settings. Questions included in the survey are related to care accessibility, provider communication, care coordination, and interactions with staf. This survey was updated in 2021 to allow respondents to report about in-person, phone, and video visits.^(30)^

The results from CAHPS Clinician & Group Survey can be used by medical practices, health systems, State agencies, and others for the following purposes:^(31)^

- To help medical practices and health systems identify where practice improvement activities are needed, and evaluate the impact of existing improvement eforts,
- To give consumers information they can use to compare individual clinicians, medical practices, or medical groups, and choose where to get their care, and
- To allow State agencies or health systems to monitor the performance of physician practices, and reward those who provide high-quality care.

In addition to sharing the versions of the surveys themselves, AHRQ shares additional questions that can be added to the survey, including open ended questions; information and tools for administering the survey; and tools for comparing the survey data to aggregated results, improving patient experiences, and sharing CAHPS scores with patients.

### Behavioral Health and Substance Use Disorders

Our nation faces a behavioral health crisis as mental health and substance use disorders are on the rise, while access to care for these conditions has become increasingly limited.^(32)^ Behavioral health is an overarching term which includes “mental health and substance abuse conditions, life stressors and crises, stress-related physical symptoms, and health behaviors.”^(33)^ As primary care is the first point of entry into the healthcare system for many people, primary care clinicians are ofen in a good position to diagnose and treat these common conditions.^(34)^ Evidence suggests that providing comprehensive behavioral health care within the primary care setting leads to improved care and reduced costs.^(35)^ AHRQ defines behavioral health and primary care integration (also referred to as “behavioral health integration”, “integrated care” and “collaborative care”)^(33)^ as:

“The care that results from a practice team of primary care and behavioral health clinicians, working together with patients and families, using a systematic and cost-effective approach to provide patient-centered care for a defined population.”^(33)^

In addition to funding contracts and research grants focused on behavioral health and behavioral health integration, AHRQ hosts the Academy for Integrating Behavioral Health and Primary Care (https://integrationacademy.ahrq.gov/), and has developed several resources in this topic area. This section of the report includes a summary of AHRQ’s primary care grants, initiatives, and resources with a main focus on behavioral health and behavioral health integration.

[image] Grants with a focus on health equity are indicated with this icon

#### Grants

There were 9 AHRQ primary care grants actively funded during FYs 2021 and 2022 that focused mainly on behavioral health or behavioral health integration. This included four R01s (Research Projects), two R18s (Research Demonstration and Dissemination Projects), one R03 (Small Research Grant), one R21 (Exploratory/ Developmental Grant), and one K08 (Mentored Clinical Scientist Development Award). An additional nine grants included some focus on behavioral health content and are described in other sections of this report, including in Practice and Quality Improvement (6) and Person-Centered Care (3).

Below are tables, organized by subtopic, which include short summaries of the 9 studies focused mainly on behavioral health or behavioral health integration. The 3 subtopics include use of digital healthcare tools in behavioral health, substance use disorders, and behavioral health integration.

##### Behavioral Health Integration

Three studies focus on behavioral health integration.

Behavioral Health Integration in Community Health Centers and Hospital Emergency Department Utilization (R03) (https://reporter.nih.gov/project-details/10364901)
PI: Kathleen Carey; Organization: Boston University Medical Campus; School of Public Health; Uses the existing variation in the level of behavioral health services provided in community health centers to examine if greater integration of behavioral health services in primary care settings leads to reductions in emergency department visits for behavioral health issues.
Implementation and Evaluation of an Evidence-Based Physical Activity Screening and Promotion Program in Six Primary Care Clinics (K08) (https://reporter.nih.gov/project-details/10098295)
PI: Sarah Elizabeth Linke; Organization: University of California, San Diego; School of Medicine; Family Medicine; Looks at the barriers and facilitators of incorporating screening and counseling for insuficient physical activity into routine primary care visits with a referral to primary care behavioral health. This study builds on evidence that counseling to increase physical activity is more efective when delivered by behavioral health providers.
Impact of a Novel Community-Based Biobehavioral Chronic Pain Team Training Program (4PCP) on Practitioner and Patient Outcomes (R01) (https://reporter.nih.gov/search/5peeSstOvU6nWJi1XcWMKg/project-details/10522098)
PI: Thomas C. Chelimsky; Organization: Virginia Commonwealth University; School of Medicine; Neurology; Looks at using a “biopsychosocial” approach to treating chronic pain rather than a “biopharmacologic” approach. This “biopsychosocial” approach treats chronic pain syndrome as a brain disorder, which has been reinforced though negative cognitive, emotional, and behavioral habits. In a previous pilot study, the researchers demonstrated that primary care practitioners were eager to implement this new approach, and those who did so had increased confidence with chronic pain management, reduced visit times, and improved patient pain. The primary care practices in this study will receive training from a paired psychologist and a physical therapist to build a clinical team. The study will examine if patient improvements can be sustained for 2 years and if increased practitioner confidence leads to a tapering of prescribed opioids.

##### Use of Digital Healthcare Tools in Behavioral Health

Three studies look at the use of digital healthcare tools in behavioral health, as described in the following table.

[image] Using eHealth to Expand Access to Cognitive Behavioral Therapy for Insomnia in Hispanic Primary Care Patients (R01) (https://reporter.nih.gov/project-details/10457288)
PI: Carmela Alcantara; Organization: Columbia University New York Morningside; Schools of Social Welfare/Work; Other Health Professions; Examines the effectiveness of an electronic health intervention to provide culturally adapted cognitive behavioral therapy to treat insomnia among Spanish-speaking Hispanic primary care patients with chronic insomnia.
[image] TRANSFORM DEPCARE: A Theoretical Approach to Improving Patient Engagement and Shared Decision Making for Minorities in Collaborative Depression Care (R01) (https://reporter.nih.gov/project-details/10214675)
PI: Nathalie Moise; Organization: Columbia University Health Sciences; School of Medicine; Internal Medicine; Examines if care manager technical assistance, provider education, and an automated shared decision-making process – with an interactive shared decision-making tool – improves clinician and patient participation in collaborative care to treat depression in primary care. Collaborative care in this study relies on care managers to provide antidepressant adherence counseling and/or psychotherapy.; Read Emerging Research Spotlight #6
Implementation of Digital Mental Health Tools in Ambulatory Care Coordination (R01) (https://reporter.nih.gov/search/n3w8ycpSwU66J2lLxt5FNw/project-details/10182581)
PI: Emily Gardiner Lattie; Organization: Northwestern University at Chicago; Domestic Higher Education; Adapts a digital mental health platform and service model to improve access to, and coordination of, mental health services in ambulatory care.

##### Substance Use Disorders

Three studies in this topic area focused on substance use disorders. In addition to the grants described in the table below, there were six grants focused on managing unhealthy alcohol use that are part of an EvidenceNOW initiative and are described in the Practice and Quality Improvement section, along with the other EvidenceNOW grants.

Two of the studies about substance use disorders described below focus on opioid use disorder. In addition to these, there are another eight AHRQ primary care grants funded during the 2021 and 2022 period that look at opioids - many of which focused on chronic pain and medication safety. The full list of the 10 opioid related grants is included in Appendix C: Opioids.

Group Well Child Care Intervention for Infants of Mothers in Treatment for Opioid Use Disorder (R18) (https://reporter.nih.gov/project-details/10335839)
PIs: Neera Goyal; Vanessa L. Short; Organization: Alfed I. Du Pont Hospital for Children; Independent Hospital; Looks at the use of comprehensive group well child visits for mothers with opiate use disorder and their children. The group visits examined in this study allow for increased time with the pediatrician, peer-to-peer learning, and an enhanced focus on behavior change and self-care.; Learn more about this study in a recent NCEPCR webinar: Qualitative Methods Used in AHRQ Funded Primary Care Research (https://www.ahrq.gov/ncepcr/about/pcr-webinar-series/qualitative-methods.html).
[image] ECHO-F Model to Expand Medication Assisted Treatment in Rural Primary Care (R18) (https://reporter.nih.gov/project-details/10221050)
PI: Julie G. Salvador; Organization: University of New Mexico Health Sciences Center; School of Medicine; Psychiatry; Uses the Extensions for Community Healthcare Outcomes (ECHO©) model, with additional supports as needed, to train primary care providers in rural New Mexico to provide medication to treat opioid use disorders.; Read Research Profile #12
Real-time Assessment of Dialogue in Motivational Interviewing Training (ReadMI) (R21) (https://reporter.nih.gov/project-details/9980343)
PI: Paul J Hershberger; Organization: Wright State University; Schools of Medicine, Family Medicine; Develops and tests Real-time Assessment of Dialogue in Motivational Interviewing (ReadMI), a tool to help train primary care clinicians to efectively use motivational interviewing for drug and alcohol misuse intervention. Motivational interviewing (MI) is a strategy clinicians can use to help patients identify and change unhealthy behaviors. ReadMI uses natural language processing to provide low-cost analysis of MI discussions and give immediate feedback to clinicians.

#### Initiatives and Resources

AHRQ developed several resources and materials related to behavioral health and substance use disorders in primary care that were ongoing or new in 2021 and 2022. These resources and materials are described below with links to additional information or to the specific material.

The Academy logo

The Academy for Integrating Behavioral Health and Primary Care (https://integrationacademy.ahrq.gov/), which was created in 2010, is a national resource and coordinating center focused on the integration of behavioral health and primary care.^(36)^ The Academy’s website serves as a centralized portal for information and materials on behavioral health integration – including a focus on using evidence-based practices to manage unhealthy alcohol use and opioid use disorder.^(37)^ The portal includes several materials developed in 2021 and 2022, as described below.

[image] Materials developed by the EvidenceNOW: Managing Unhealthy Alcohol Use (https://integrationacademy.ahrq.gov/about/initiatives/alcohol) initiative
  ■ Unhealthy Alcohol Use Tools & Resources (https://integrationacademy.ahrq.gov/products/substance-use-resources/environmental-scan/unhealthy-alcohol-use) is an online compendium of tools and resources for clinicians and clinical teams, health system leaders, and patients to support the implementation of evidence-based approaches to manage unhealthy alcohol use.
  ■ The Overview of Medications Used in the Treatment of Alcohol Use Disorder and Frequently Asked Questions (https://integrationacademy.ahrq.gov/sites/default/files/2022-11/Medications%20for%20Alcohol%20Use%20FAQ.pdf) includes information about medications approved by the Food and Drug Administration (FDA) for treatment of alcohol use disorder to assist primary care clinicians.
  ■ Implementing Screening and Treatment of Unhealthy Alcohol Use During COVID-19 (https://www.ahrq.gov/news/blog/ahrqviews/unhealthy-alcohol-use-during-covid19.html) is a blog post from AHRQ’s Senior Staf Fellow Sebastian Tong, MD MPH on the increased need for screening and treatment for unhealthy alcohol use in primary care during the COVID-19 pandemic.
[image] Materials developed by the AHRQ Older Adult Opioid Initiative (https://integrationacademy.ahrq.gov/about/initiatives/older-adult-opioid-initiative)
  ■ Identifying and Testing Strategies for Management of Opioid Use and Misuse in Older Adults in Primary Care Practices: Opioid and Pain Management Tools and Resources (https://integrationacademy.ahrq.gov/sites/default/files/2021-04/Table_of_Opioid_and_Pain_Management_Tools_and_Resources.pdf). This set of tools and resources can be used for the management of opioids in older adults in primary care practices and includes descriptions, empirical evidence, applicability to older adults and/or primary care practices, and links to resources.
  ■ Management of Opioid Use and Misuse in Older Adults: High-Leverage Changes for Improvement (https://integrationacademy.ahrq.gov/sites/default/files/2021-04/High_Leverage_Changes_for_Management_of_Opioid_Use_and_Misuse_in_Older_Adults.pdf) is an infographic providing an overview of change strategies to improve the management of chronic pain and opioid use and misuse among older adults in primary care.

Many other products (https://integrationacademy.ahrq.gov/products) are currently available on the Academy website, and new resources are developed and shared regularly.

Six Building Blocks: A Team-based Approach to Improving Opioid Management in Primary Care – How-To-Implement Toolkit

This implementation guidance provides a roadmap for healthcare organizations to improve care treatment for patients using long-term opioid therapy to treat chronic pain.^(38)^ Afer reviewing How-To-Implement Toolkit: Overview (https://www.ahrq.gov/sites/default/files/wysiwyg/patient-safety/settings/ambulatory/6bb-toolkit-overview-rev.pdf) to determine which approach fits best, organizations can select the Fast-Track or Full Program Approach. Each approach includes implementation guides, a self-assessment tool (https://www.ahrq.gov/sites/default/files/wysiwyg/patient-safety/settings/ambulatory/6bb-self-assess-tool.pdf), and additional resources.

### Health Equity

The Centers for Disease Control and Prevention (CDC) defines health equity as “the state in which everyone has a fair and just opportunity to attain their highest level of health.”^(39)^ Back in 2001, the Institute of Medicine (now the National Academy of Medicine) report Crossing the Quality Chasm: A New Health System of the 21st Century, called for making health care equitable in addition to being safe, effective, person-centered, timely, and efficient. Unfortunately, more than 20 years later, inequitable health outcomes persist across racial/ethnic and socioeconomic groups in the U.S.^(40)^.

In 2021, the National Academy of Sciences, Engineering, and Medicine (NASEM) observed that “primary care is the only health care component where an increased supply is associated with better population health and more equitable outcomes.”^(27)^ Given this, eforts to increase access to primary care (through locating practices in the communities where patients live, expanded hours and telehealth options, and transformations in healthcare payment models) have the potential to improve health equity.^(41)^ However, careful research, monitoring, and evaluation are needed to ensure that these eforts are efective and are not introducing new and unintended consequences.

For twenty years, AHRQ has published the National Healthcare Quality and Disparities Report, which shows trends in health care disparities by race, ethnicity, and social determinants of heath.^(42)^ AHRQ has also invested in a small number of primary care research grants focused on examining and addressing health inequities. This section of the report includes a summary of AHRQ’s primary care grants and resources with a main focus on advancing health equity.

#### Grants

Seven AHRQ primary care grants actively funded during FYs 2021 and 2022 focused mainly on examining or addressing health inequities, including four R01s (Research Projects), two K01s (Research Career Programs), and one K08 (Clinical Investigator Award). Another 25 grants had at least some focus on health equity and are described elsewhere in this report, including in Healthcare Systems and Infrastructure (6), Practice and Quality Improvement (4), Digital Healthcare (3), Behavioral Health and Substance Use Disorders (3), Person-Centered Care (3), Primary Care Workforce (1), Public Health and Community Integration (1), and COVID-19 (1).

[image] Grants with a focus on health equity can be found throughout the report, and are indicated with this icon

[image] Federally Qualified Health Centers and Care for Vulnerable Populations (R01) (https://reporter.nih.gov/project-details/10167765)
PI: Vicki Fung; Organization: Massachusetts General Hospital; Independent Hospital; Examines whether the Patient Protection and Afordable Care Act (ACA)-related funding increases for federally qualified health centers are associated with improvements in outpatient care; downstream clinical efects including emergency department visits, hospitalizations, and mortality; and total spending for Medicaid patients.
[image] Examining The Impact of Healthcare Systems Changes on Healthcare Use and Health Outcomes for Children (R01) (https://reporter.nih.gov/search/n66NDW8nr0i-RMPuB6Y4sw/project-details/10513989)
PI: Sarah Beal; Organization: Cincinnati Children’s Hospital Medical Center; Independent Hospital; Evaluates the impact of diferent delivery models on health outcomes for children in foster care and examines the factors that contribute to variations in healthcare use and health outcomes for these youth. The findings can be used to implement health delivery practice changes, ofen in primary care, to improve the health outcomes of these vulnerable youth.; Read Emerging Research Spotlight #7
[image] Reducing Use of Antibiotics Without a Prescription Among Outpatients in a Safety Net Healthcare System (R01) (https://reporter.nih.gov/project-details/10379940)
PIs: Barbara Wells Trautner; Larisa Grigoryan; Organization: Baylor College of Medicine; School of Medicine; Internal Medicine; Examines how factors at the patient, healthcare system, and clinician encounter levels predict use of non-prescribed antibiotics by patients seen in safety net primary care clinics who are predominantly uninsured and ofen have low incomes. This work will result in the development of a communication tool designed to help clinics guide their patients toward safer antibiotic use.
[image] Leveraging Linked Data to Evaluate Social and Spatial Disparities in Contraception Access and Regional Program Impacts (K01) (https://reporter.nih.gov/project-details/10268206)
PI: Jessica N Sanders; Organization: University of Utah; Uses a matched-control design to evaluate the impacts of a county-level contraceptive initiative on unintended pregnancies and birth outcomes at a population-level. The study will also use linked all-payer claims, electronic medical records, geospatial markers, demographic profiles, and birth certificates to identify regional disparities in family planning access and outcomes.
[image] The Efect of Rurality and the COVID-19 Pandemic on Telemedicine and Preventive Healthcare Use (K01) (https://reporter.nih.gov/project-details/10524679)
PI: Annie Elizabeth Larson; Organization: OCHIN, INC; Investigates the role of telemedicine in improving access to primary care for rural patients. The research team is looking at the frequency and type of preventive care visits, diferences between urban and rural patients on uptake of telemedicine, and the efect of telemedicine on the quality and equity of care for chronic health conditions among rural and urban patients. Learn more about this study in a recent NCEPCR webinar: Using Large Datasets in Primary Care Research (https://www.ahrq.gov/ncepcr/about/pcr-webinar-series/large-datasets.html).
[image] The Cost of Illness: The Impact of COVID-19 on Patient Financial Outcomes (K08) (https://reporter.nih.gov/project-details/10586963)
PI: Nora V Becker; Organization: University of Michigan at Ann Arbor; School of Medicine; Internal Medicine; Examines “financial toxicity,” or the financial consequences of illness. The grant first investigates which patient subgroups are at the highest risk of financial burden; then estimates the objective financial burden of a COVID-19 infection; and assess patients’ subjective financial distress related to their illness. This study is focused on a topic integral to primary care.
[image] Multi-State, Mixed-Methods Evaluation of the Uptake of New Direct Acting Antiviral Regimens for the Treatment of Hepatitis C Virus (R01) (https://reporter.nih.gov/project-details/10222770)
PI: Karen M Clements; Organization: University of Massachusetts Medical School, Worcester; Uses claims analyses to examine uptake of newer and more efective direct-acting antiviral (DAA) treatment for hepatitis C virus among Medicaid populations across multiple states. The research team will also identify the patient, provider, and contextual factors that predict DAA treatment.

#### Initiatives and Resources

Since 2003, AHRQ has annually published the National Healthcare Quality and Disparities Report (NHQDR) to summarize the status of health and healthcare delivery in the US, identifying areas of strength, weaknesses, and disparities for access to and quality of healthcare. Quality is described in six categories in the report: patient safety, patient-centered care, care coordination, efective treatment, healthy living, and care afordability. The 2021 and 2022 NHQDRs are described in the tables below, along with some key findings.

2021 National Healthcare Quality and Disparities Report (https://www.ahrq.gov/research/findings/nhqrdr/nhqdr21/index.html)

The data reported in the 2021 NHQDR were collected in 2019 or earlier, prior to the start of the COVID-19 public health emergency. This report serves as a defining “snapshot” of where the US healthcare system stood prior to the start of the COVID-19 pandemic response.

Areas of improvement documented between the early 2000s and 2018 include:

■ decreased death rates for HIV, heart disease, and colon cancer;
■ more people under age 65 have health insurance coverage;
■ decreased personal spending on health insurance and healthcare services for people under age 65 with public insurance;
■ improvements in healthcare quality for Black, Hispanic, and American Indian and Alaska Native communities, although significant disparities still exist.

Areas of ongoing challenge include the following:

■ Despite decreases in HIV death rates, including among Black people, the HIV death rate for Black people is still more than six times the rate for White people.
■ Poor access to dental care and oral healthcare services are ongoing, particularly among people who have a low income or who live in rural areas.
■ The opioid and mental health crisis have continued to worsen, including worsening suicide death rates between 2008 and 2018 and increased opioid-related emergency department visits between 2005 and 2018.

2022 National Healthcare Quality and Disparities Report (https://www.ahrq.gov/research/findings/nhqrdr/nhqdr22/index.html)

The data reported in the 2022 NHQDR were collected in 2020 and prior, and therefore include information on the first year of the COVID-19 public health emergency.

Some findings reported in the 2022 NHQDR include the following:

■ While the percentage of people with health insurance coverage has increased overall, Hispanic groups, non-Hispanic American Indians, and Alaskan Natives are significantly less likely to have health insurance than other groups
■ Life expectancy in the US decreased for the first time in 2020, because of the COVID-19 pandemic. This decline was worse for Hispanic and non-Hispanic Black groups than for non-Hispanic White groups, continuing to exacerbate health disparities between these groups. The leading cause of death in 2020 in the US was heart disease, cancer, COVID-19, and unintentional injuries. The most common unintentional injury was drug overdose, accidental falls, and motor vehicle accidents.
■ While the number of workers in ambulatory healthcare settings significantly declined at the start of the COVID-19 public health emergency, employment in those settings has recovered. However, the number of healthcare workers continues to decrease in hospitals and nursing and residential care settings, particularly for the roles that require less educational attainment.

The 2022 NHQDR highlights four Special Emphasis topics that are priority issues for the Biden-Harris Administration, including maternal health, child and adolescent mental health, substance use disorders, and oral health.

### Primary Care Workforce

Ensuring that everyone in the U.S. has access to high-quality primary care, as recommended by the National Academies of Sciences, Engineering and Medicine (NASEM)^(27)^, requires a robust and stable primary care workforce. However, the U.S. currently faces a concerning shortage of primary care physicians, as well as an inequitable distribution of primary care clinicians (including physicians, nurse practitioners [NPs], and physician assistants [PAs]) across the country.^43)^

The primary care physician workforce in the U.S. is shrinking,^(44)^ with a projected shortage unable to meet patient demand by 2035.^(45)^ The proportion of health care trainees who choose to focus on primary care has decreased in recent years, and primary care training disproportionally takes place in hospitals rather than in the community settings where primary care services mainly occur.^(27,^ ^44)^ In addition, there is wide variation in the proportion of primary care clinicians serving different areas across the U.S., resulting in growing gaps in access to care in medically underserved communities.^(27)^

Unfortunately, the COVID-19 public health emergency exacerbated challenges with primary care workforce well-being, including increased workload, work-related stress, and emotional distress^(46)^. In 2022, more than half of family physicians reported symptoms of burnout.^(47)^ In addition to the personal toll on physicians and their families, burnout has been found to lead to poorer quality of care, lower patient satisfaction, and decreased patient safety.^(47–49)^ Low physician well-being, professional satisfaction and high burnout leads some clinicians to reduce their hours or leave practice altogether, further exacerbating workforce shortages.^(47)^

Research is needed to better understand how to effectively expand and diversify the primary care workforce, mitigate burnout, and to examine how to best support primary care teams in communities throughout the U.S. AHRQ has identified primary care workforce as a topic area of interest, although investments in 2021 and 2022 were limited to a small number of grants (including a conference), as described in this section. Studies that measure, track, and contribute to understanding the experience of the primary care workforce are necessary to ensure access to quality primary care.

#### Grants

Four AHRQ primary care grants actively funded during FYs 2021 and 2022 were focused mainly on the primary care workforce. This included two R03s (Small Research Grants), one R13 (Support for Conferences and Scientific Meetings), and one K08 (Mentored Clinical Scientist Development Award). In addition to these four grants, one other grant included primary care workforce as a component, and is described in the Healthcare Systems and Infrastructure section.

Below are tables, organized by two subtopics, which include short summaries of the four studies focused mainly on the primary care workforce. Subtopics include expanding the primary care workforce with nurse practitioners and measuring individual and team factors afecting the primary care workforce.

[image] Grants with a focus on health equity are indicated with this icon

##### Expanding the Primary Care Workforce with Nurse Practitioners

Two studies look at expanding the primary care workforce with a focus on nurse practitioners, as described in the following table.

Advancement of Research on Nurse Practitioners (ARNP): Setting a Research Agenda (R13) (https://reporter.nih.gov/project-details/10088080)
PI: Lusine Poghosyan; Organization: Columbia University Health Sciences; School of Nursing; Other Health Professions; Organizes a research conference to advance research on NPs in primary care. The focus of the conference is on identifying barriers and facilitators afecting the NP workforce, strategies to overcome those challenges, and the development of a research agenda to produce evidence to support the expansion of NPs in primary care.
[image] The Role of Nurse Practitioners in Improving Access to Primary Care (R03) (https://reporter.nih.gov/project-details/10450283)
PI: Hannah Toby Neprash; Organization: University of Minnesota; School of Public Health; Public Health and Preventative Medicine; Develops a national database of all-payer claims and electronic health record data to examine how much adding nurse practitioners to primary care teams increases access to care, particularly for patient populations that have traditionally faced barriers to access.; Read Emerging Research Spotlight #8

##### Measuring Individual and Team Factors Affecting the Primary Care Workforce

Two studies focus on new measures of methods for measuring individual and team factors affecting the primary care workforce

Validation of the Primary Care Team Creativity Tool (PCTC) (R03) (https://reporter.nih.gov/project-details/10133052)
PI: Yuna Swatlian Hiratsuka Lee; Organization: Columbia University Health Sciences; School of Public Health; Public Health & Preventive Medicine; Validates a newly developed survey tool focused on measuring primary care team creativity, measuring how well teams work together and generate novel and useful strategies to solve complex challenges in primary care.
Development and Validation of a Prediction Model to Address Physician Burnout (K08) (https://reporter.nih.gov/project-details/10252902)
PI: Daniel Tawfik; Organization: Stanford University; Domestic Higher Education; Develops and validates a prediction model that uses existing operational data to identify primary care clinics at high-risk for clinician burnout.; Read Research Profile #13

#### Initiatives and Resources

AHRQ did not have any new initiatives or resources related to primary care workforce during 2021 and 2022.

### Public Health and Community Integration

The COVID-19 pandemic made clear the need to better connect primary care with public health to improve population health through coordination of eforts such as disease surveillance and contact-tracing. There is also growing awareness about the need for primary care practices to be closely integrated with a range of social service organizations within the community. Evidence shows that social determinants of health (SDOH) – the underlying social, economic, and environmental factors that impact health – drive as much as 80% of health outcomes.^(50)^ SDOH include socioeconomic factors (e.g., education and income levels), neighborhood and built environment, social and family support, and community safety. Increasingly, primary care practices and healthcare systems are working to provide care that is responsive to SDOH, including integrating screening for social needs into clinical care services, and collocating or collaborating with community services.

AHRQ prioritizes supporting clinical-community linkages (https://archive.ahrq.gov/ncepcr/tools/community/index.html) to improve patients’ access to care by connecting healthcare providers, public health agencies, and community organizations.^(51)^ Through these connections, communities are better able to build strong partnerships to help fill gaps in services and promote healthy behaviors. While AHRQ has identified Public Health and Community Integration in primary care as a topic area of interest, their research investments in 2021 and 2022 with a main focus on this topic were limited to a small number of grants and resources described in this section.

[image] Grants with a focus on health equity are indicated with this icon

#### Grants

Two AHRQ primary care grants actively funded during FYs 2021 and 2022 were mainly focused on public health and community integration, including one R36 (Dissertation Award) and one R18 (Research Demonstration and Dissemination Project). An additional seven grants had some focus on public health and community integration and are described elsewhere in this report depending on the main focus of the grant, including in Practice and Quality Improvement (2), Person-Centered Care (2), Healthcare Systems and Infrastructure (1), and Digital Healthcare (1).

Below is a table with summaries of the two primary care grants with a main focus on public health and community integration.

[image] Patients’ Decisions and Perspectives Regarding Healthcare-Based Social Risk Interventions (R36) (https://reporter.nih.gov/project-details/10048868)
PI: Anna Steeves-Reece; Organization: Oregon Health & Science University; Overall Medicine; Assesses patient perspectives on a healthcare-based social risk intervention at healthcare sites, including primary care clinics, which links the EHR with a social risk screening tool to support the referral of Medicaid and Medicare patients to community resources to address their needs.; Learn more about this study in a recent NCEPCR webinar: Qualitative Methods Used in AHRQ Funded Primary Care Research (https://www.ahrq.gov/ncepcr/about/pcr-webinar-series/qualitative-methods.html).
Using Social and Medical Data Integration to Improve Primary Care and Population Level Chronic Disease Prevention and Management (R18) (https://reporter.nih.gov/project-details/10259697)
PIs: Danielle Marie Hessler-Jones; Caroline M Fitchenberg; Organization: University of California, San Francisco; School of Medicine; Family Medicine; Integrates a Community Information Exchange, a multi-organization data-sharing system designed to improve care coordination, into the EHRs of three Federally Qualified Health Centers. The grant uses a human-centered design process to understand barriers and facilitators to efective implementation, identifies factors that influence the use and uptake of these EHR dashboards, and evaluates the impact on patient care and population health management.; Read Emerging Research Spotlight #9

#### Initiatives and Resources

In addition to supporting clinical-community linkages (https://archive.ahrq.gov/ncepcr/tools/community/index.html), AHRQ works to help healthcare systems and clinicians build understanding of SDOH and the social needs of patients (https://www.ahrq.gov/sdoh/practice-improvement.html) to improve healthcare. An ongoing AHRQ SDOH database and a resource on addressing social needs in primary care from 2021 are described below.

Social Determinants of Health Database (https://www.ahrq.gov/sdoh/data-analytics/sdoh-data.html)

AHRQ’s SDOH database helps to facilitate patient centered outcomes research by allowing researchers to find a range of well documented and readily linkable SDOH variables without needing to access multiple source files. The SDOH Database was updated in July 2022 and now includes data through 2020 at the county, ZIP code, and census tract levels. Variables in the files correspond to five key SDOH domains: social context (e.g., age and race), economic context (e.g., income), education, physical infrastructure (e.g., housing and transportation), and healthcare context (e.g., health insurance).

Identifying and Addressing Social Needs in Primary Care Settings (https://www.ahrq.gov/sites/default/files/wysiwyg/evidencenow/tools-and-materials/social-needs-tool.pdf)

Collecting information about a patient’s social needs can be used to help connect them to needed services available in the community, and also helps clinicians develop treatment plans that are tailored to the patient’s unique needs and priorities. Social needs are what a patient perceives as what they need to address the negative SDOH they face. This tool is designed to help primary care practices start screening patients for social needs, and includes information about various screening tools and resources, different approaches for implementing social needs screening, and considerations for what practices can do with the social needs information they collect.

## Additional Topic Areas

This section covers two additional topics that are of interest to AHRQ and are relevant for primary care researchers and clinicians: COVID-19 and Patient Safety. While most of the grants related to these topic areas are already included in the key topic areas covered in the previous section, the grants included in this section did not fit into any of the key topic areas.

### COVID-19

Both primary care practice and primary care research experienced unprecedented disruptions due to the COVID-19 public health emergency. During the height of the pandemic, many primary care practices understandably needed to put their full focus on providing care for patients, keeping their workforce safe, and surviving financially. This frequently meant that practice-based research was either delayed or severely curtailed during this time^(52)^. At the same time, however, the COVID-19 pandemic created new primary care relevant research questions and opportunities, including understanding the impacts of telehealth use on healthcare access, utilization, safety, and equity. New challenges have emerged for primary care and primary care research in the wake of COVID-19, including addressing the health impacts of social isolation, finding efective treatments for people living with long COVID, and dealing with increased shortages and burnout across the primary care workforce.

AHRQ supported the nation’s response to COVID-19 through ongoing work in practice improvement, health systems research, and data and analytics.^(53)^ AHRQ’s specific response to COVID-19, included research grant awards, several blog posts by AHRQ leadership, and many relevant publications (found here (https://www.ahrq.gov/coronavirus/index.html)).

[image] Grants with a focus on health equity are indicated with this icon

#### Grants

A total of 11 AHRQ primary care grants funded in FYs 2021 and 2022 examine issues related to COVID-19. Four of these grants are COVID-19 Research Grant Awards (https://www.ahrq.gov/coronavirus/grants.html), funded specifically to “explore essential questions about the delivery of healthcare” during the pandemic.^(54)^ Among these four grants, described in the table below, two are new research projects [both R01s (Research Projects)], and two are supplemental funding to existing grants with a focus on COVID-19 [both R18s (Research Demonstration and Dissemination Projects)]. The additional seven primary care grants looking at issues related to COVID-19 are described in other topic area sections in this report [Practice and Quality Improvement (2), Health Equity (2), Healthcare Systems and Infrastructure (1), Digital Healthcare (1), and Person-Centered Care (1)]. A full table of the 11 COVID-19 related grants is included in Appendix C: COVID-19.

[image] A Multi-Site Evaluation of Primary Care Accessibility and Utilization during COVID-19 (R01) (https://reporter.nih.gov/project-details/10318612)
PIs: Raj M. Ratwani and Ethan A. Booker; Organization: Medstar Health Research Institute; Examines the impact of COVID-19 disruptions on access and utilization of primary care for patients in three healthcare systems. The study looks at which patients received care via which modalities (in-person, telehealth, or both); what subpopulations were disproportionately afected by disruptions in care; and the barriers and facilitators to telehealth across the three sites.
Quality, Safety, Value: Impact of Sudden Shif to Telehealth Due to COVID-19 Within Nurse-Led Care Models Located in Colorado Rural and Urban Communities (R01) (https://reporter.nih.gov/project-details/10321967)
PI: Amy J. Barton; Organization: University of Colorado Denver; School of Nursing; Examines the impact of the sudden shif to telehealth for behavioral health, primary and prenatal care, and home visitation appointments, as a response to the COVID-19 pandemic, on innovative nurse-led care models used to provide care throughout Colorado. The research team considers utilization, both intended and unintended patient outcomes, as well as provider and patient experiences.; Read Research Profile #14
Integrating Patient-Reported Outcomes into Routine Primary Care: Monitoring Asthma Between Visits (R18) (https://reporter.nih.gov/project-details/10175400)
PI: Robert Samuel Rudin; Organization: RAND Corporation; This supplemental project enhances a mobile health intervention for home monitoring of asthma symptoms between primary care visits by adding COVID-19 symptom screening and information. This supplemental project to an existing grant enhances a mobile health intervention for home monitoring of asthma symptoms with COVID-19 symptom screening and information. [Read about the parent study (https://reporter.nih.gov/project-details/9984366), with the same name as this supplemental grant, in the Digital Healthcare section of this report].; Read Emerging Research Spotlight #10
[image] Partnership for Medication Safety in Primary Care and Telehealth during COVID-19 Public Health Crisis (R18) (https://reporter.nih.gov/project-details/10175928)
PI: Yan Xiao; Organization: University of Texas Arlington; This supplemental grant evaluates the impact of changes in visit modalities due to COVID-19, such as the use of telehealth on access and safety. Based on the findings of this evaluation, the research team will develop practice guidelines to help primary care clinics provide safe and equitable care during disruptions brought on by the pandemic. [Read about the parent study PROMIS Learning Lab: Partnership in Resilience for Medication Safety (https://reporter.nih.gov/project-details/10251914) in the Healthcare Systems and Infrastructure section of this report].

#### Initiatives and Resources

AHRQ funded the development of materials and resources to support primary care clinicians and researchers during COVID-19, and shared their lessons learned. As described below, this includes key take-aways from a primary care learning community, as well as learnings from the EvidenceNOW: Managing Unhealthy Alcohol Use initiative.

AHRQ’s Primary Care COVID-19 Learning Community

AHRQ initiated a learning community in late 2020 to bring together the primary care community as it dealt with COVID-19, for the purpose of facilitating shared learning and peer support and surfacing promising responses. Participants included 250 professionals, including clinicians and other team members, researchers, policy makers, advocates, quality improvement professionals, and representatives from primary care-related organizations. The learning community came together through eight virtual meetings held across an 11-month period. In addition to expert presentations and panel discussions on select topics, each meeting included small or large group discussions for participants to share their experiences from the field.

Insights from the learning community, including lessons learned and primary care innovations in response to the pandemic, have been distilled in the summary publication Primary Care’s Challenges and Responses in the Face of the COVID-19 Pandemic: Insights from AHRQ’s Learning Community (https://pubmed.ncbi.nlm.nih.gov/36690493/).

Conducting Primary Care Research During COVID-19

The EvidenceNOW: Managing Unhealthy Alcohol Use initiative (described in the Practice and Quality Improvement section of this report) was launched in 2019, shortly before COVID-19 disruptions upended the projects’ research plans and timelines. The initiative leaders and grantees shared their challenges and lessons learned about conducting primary care research during this dificult time through publications, a webinar, and a blog.

Insights from the learning community, including lessons learned and primary care innovations in response to the pandemic, have been distilled in the summary publication Primary Care’s Challenges and Responses in the Face of the COVID-19 Pandemic: Insights from AHRQ’s Learning Community.

■ Implementing Screening and Treatment of Unhealthy Alcohol Use During COVID-19 (https://www.ahrq.gov/news/blog/ahrqviews/unhealthy-alcohol-use-during-covid19.html) – this blog by Sebastian Tong, MD MPH – a family physician who had been serving as a Senior Staf Fellow at AHRQ, describes both the increased dificulty with conducting practice-based research during COVID-19, as well as the importance of screening for and treating unhealthy alcohol use during this time of increased stress and social isolation.
■ Primary Care Research During the COVID-19 Pandemic: Perspectives from AHRQ’s Unhealthy Alcohol Use Grantees (https://integrationacademy.ahrq.gov/news-and-events/news/new-webinar-primary-care-research-challenges-during-covid-19) – this webinar from March 2021, featuring two AHRQ grantees, discusses challenges and solutions during COVID-19 related to recruiting practices and maintaining their engagement, as well as data collection and human subjects’ protections.
■ Primary Care Research Is Hard to Do During COVID-19: Challenges and Solutions (https://www.annfammed.org/content/20/6/568) – this article outlines challenges faced across 15 research projects, and strategies to address these challenges. The authors recommended that researchers and funders embrace pragmatic and adaptive designs.
■ Barriers to Recruiting Primary Care Practices for Implementation Research During COVID-19: A Qualitative Study of Practice Coaches from the Stop Unhealthy (STUN) Alcohol Use Now Trial (https://journals.sagepub.com/doi/full/10.1177/26334895221094297) – this article examines the barriers and facilitators for practice-based research during the COVID-19 pandemic through interviews with practice facilitators.

### Patient Safety

Patient safety aims to prevent and reduce the potential risks, errors, and harms to patients that can occur during the provision of health care.^(55)^ Threats to patient safety in primary care settings include diagnostic errors or delays; medication errors, including inappropriate or overprescribing; breakdowns in communication between clinicians and patients and families, or within clinical teams; and fragmentation of care.^(56)^ In addition, many primary care patients continue to receive referrals for low-value screenings and tests that have been shown to have high rates of false-positive results.^(57)^ This can set of a cascade of patient harms including anxiety, financial burden, and unnecessary treatments which can have their own physical harms. However, primary care also plays an important role in reducing common patient harms, such as preventing avoidable hospital admissions and readmissions.^(58)^ As described in AHRQ’s Guide to Improving Patient Safety in Primary Care Settings by Engaging Patients and Families (https://www.ahrq.gov/sites/default/files/wysiwyg/professionals/quality-patient-safety/patient-family-engagement/pfeprimarycare/pfepc-fullguide-final508.pdf), the strong and trusting relationships forged in primary care through patient and family engagement are essential for ensuring that care is safe and efective^.(59)^.

AHRQ has funded many primary care grants related to patient safety as well as several patient safety resources for the primary care or ambulatory care setting, as described below.

[image] Grants with a focus on health equity are indicated with this icon

#### Grants

A total of 30 AHRQ primary care grants funded in FYs 2021 and 2022 look at issues of patient safety, including reducing diagnostic errors, improving medication management, and antibiotic stewardship. All but three of these grants also had another topic focus and are described in other sections of this report [Practice and Quality Improvement (12), Digital Healthcare (9), Person-Centered Care (3), Behavioral Health and Substance Use Disorders (1), and Health Equity (1), and Primary Care Workforce (1)]. The three patient safety grants not already described in the key topic area sections are described in the table below, including two R18s (Research Demonstration and Dissemination Projects) and one R01 (Research Project). A full table of the 30 primary care grants with a focus on patient safety is included in Appendix C: Patient Safety.

Enhancing Antibiotic Stewardship in Primary Care (R01) (https://reporter.nih.gov/search/S2tjTYjr80aO-buANjtt_g/project-details/10374762)
PI: Mark Herbert Ebell; Organization: University of Georgia; Public Health and Preventive Medicine; This observational study collects and examines data on the clinical presentation, evaluation, management, and outcomes for 1400 patients with lower respiratory tract infections. The research team will use the findings to develop tools primary care clinicians can use to efectively identify patients who are likely to have an uncomplicated treatment course. The goal is to help reduce inappropriate antibiotic prescriptions and the related costs and harms of inappropriate antibiotic use.
Watchful Waiting as a Strategy for Reducing Low-value Spinal Imaging (R18) (https://reporter.nih.gov/project-details/10468663)
PI: Joshua J Fenton; Organization: University of California at Davis; Internal Medicine; Refines and evaluates a simulated intervention, which uses actors playing patients, to teach primary care physicians to build skills recommending watchful waiting to patients who request low-value and potentially harmful imaging for low back pain. This study has the potential to develop useful communication strategies that primary care physicians can use to steer patients aways from potentially harmful testing while maintaining the patient-doctor relationship.
Leveraging Evidence-based Practices for Ambulatory VTE Patients to be Safe with Direct Oral Anticoagulants: LEAVE Safe with DOACs (R18) (https://reporter.nih.gov/project-details/10165790)
PI: Alok Kapoor; Organization: University of Massachusetts, Medical School Worcester; Internal Medicine; A multidisciplinary nonprofit organization recently published the direct oral anticoagulants (DOAC) Checklist for Optimal Care Transitions to elaborate the steps required to ensure a safe transition of care in ambulatory venous thromboembolism (VTE) patients. This project operationalizes the items of the Checklist to create a comprehensive care transition intervention that can be delivered by clinical pharmacists and a pharmacy technician. The care transition intervention will have the potential to prevent DOAC-related medication errors, improve the quality of care during care transitions, and increase patient knowledge and medication adherence

#### Initiatives and Resources

The Center for Quality Improvement and Patient Safety (https://www.ahrq.gov/cpi/centers/cquips/index.html) (CQuIPS) is the organizational center within AHRQ that works to improve the quality and safety of health care, and includes several AHRQ programs.^(60)^ While the focus of AHRQ’s patient safety programs and initiatives are broader than primary care, there are several recent resources that are primary care specific, which are described below. Additional AHRQ patient safety initiatives and resources (https://www.ahrq.gov/patient-safety/index.html) can be found on AHRQ’s website, including the Making Healthcare Safer III (https://www.ahrq.gov/research/findings/making-healthcare-safer/mhs3/index.html) report, as well as several resources that are tailored specifically for the ambulatory care setting (https://www.ahrq.gov/patient-safety/settings/ambulatory/index.html).

Healthcare-Associated Infections (HAI) Program (https://www.ahrq.gov/hai/index.html)

AHRQ’s HAI program funds research and implementation projects that advance the science of HAI prevention, develop more efective approaches for reducing HAIs, and help frontline clinicians better understand how to apply proven methods to make care safer.^(61)^

■ A recent primary care relevant resource from the HAI program is the Toolkit to Improve Antibiotic Use in Ambulatory Care (https://www.ahrq.gov/antibiotic-use/ambulatory-care/index.html). The Toolkit explains the Four Moments of Antibiotic Decision Making and how they can be applied in practice, with a focus on improving antibiotic stewardship, strategies for communicating with patients and families about antibiotic prescribing and follow-up, and best practices for diagnosing and managing infectious syndromes as well as allergies to antibiotics.^(63),(64)^

Patient Safety Network (PSNet) (https://psnet.ahrq.gov/)

AHRQ’s PSNet is a searchable database of resources related to patient safety across healthcare settings. PSNet content includes publications, perspectives, innovations, toolkits, primers, trainings, and events – and can be searched using keywords and filters to narrow your results. A few examples of primary care relevant content from 2021 and 2022 on PSNET include:

■ Primary Care and Patient Safety: Opportunities at the Interface: (https://psnet.ahrq.gov/perspective/primary-care-and-patient-safety-opportunities-interface) a Perspective from September 2022
■ Patient Safety in the Ambulatory Care Setting; (https://psnet.ahrq.gov/perspective/patient-safety-ambulatory-care-setting) An Annual Perspective from August 2022
■ Telehealth and Patient Safety: (https://psnet.ahrq.gov/primer/telehealth-and-patient-safety) A Primer from December 2022

Patient Safety Organization (PSO) Program (https://pso.ahrq.gov/?_gl=1*18cbidi*_ga*MTk3MzI5OTg5Ni4xNjc4NDgwNzg5*_ga_1NPT56LE7J*MTY4NzQ1MjkxMC43MS4xLjE2ODc0NTQ1NDUuNjAuMC4w)

AHRQ’s PSO program oversees the listing process for PSOs, development and maintenance of the AHRQ Common Formats and the network of patient safety databases, and provides technical assistance to PSOs, providers and the public.^(62)^

■ Common Formats for Event Reporting - Diagnostic Safety Version 1.0 (https://www.psoppc.org/psoppc_web/publicpages/commonFormatsDSV1.0) – these standardized definitions and formats are designed to make it possible collect and compare patient safety information to improve learning about patient safety. While The Common Formats were developed for use by healthcare providers working with PSOs, they are available in the public domain to encourage their widespread adoption.^(65,^ ^66)^

Calibrate DX: A Resource to Improve Diagnostic Decisions (https://www.ahrq.gov/patient-safety/settings/multiple/calibrate-dx.html#:~:text=Calibrate%20Dx%20is%20designed%20to%20be%20used%20by,strategies%20that%20can%20be%20applied%20in%20operational%20settings.)

This guide walks clinicians through steps and exercises to help them evaluate and improve their diagnostic performance. This guide is meant for all clinicians whose practice includes diagnosis, including primary care clinicians.

The Five Principles of Efective Primary Care-Base Care Coordination for Reducing Potentially Preventable Readmissions (https://www.ahrq.gov/sites/default/files/wysiwyg/patient-safety/rev-reportaddendum.pdf)

These principles were developed based on a technical expert panel, an environmental scan, and key informant interviews (described here (https://www.ahrq.gov/sites/default/files/wysiwyg/patient-safety/rev-finalreport-update-2021.pdf)).

These principles were developed based on overarching concepts primary care practices can incorporate into their strategic management to help reduce hospital readmissions. The ways these are applied vary based on practices’ patient population and resources, as well as other relevant local factors.