# 8. Appendix D Grant Summaries

## Research Profiles

This section includes summaries of selected studies that have at least some relevant publications and findings to report.

### P1 Does A New Care Model Improve Care for Patients with Acute Kidney Injury After Hospital Discharge?

This grant funded the implementation of a pilot feasibility trial evaluating a program that supports patients discharged from the hospital to home afer an episode of acute kidney injury. The program is designed to improve patient kidney health, knowledge, and safety, while filling gaps in care and improving quality.

Erin Frazee Barreto, PharmD, RPh

PI Name: Erin Frazee Barreto, PharmD, RPh

Grant Title: Enhanced kidney follow-up for AKI survivors in Care Transitions (the ACT Study) (https://reporter.nih.gov/search/B59UQqJZJkyq8uJT-klgLg/project-details/10395486)

Organization Name: Mayo Clinic Rochester

Grant Type: R03 (Small Research Grant)

Grant Period: 05/1/2021 – 04/30/2023

Topic Areas: Practice and Quality Improvement, Healthcare Systems/Infrastructure, Patient Safety

#### Study Overview

Problem: Survivors of acute kidney injury (AKI) are at increased risk of re-hospitalization and poor health, due in part to gaps in the kidney-focused care and education provided during their care transition afer discharge from the hospital.

Main Objective: To evaluate the Acute Kidney Injury in Care Transitions (ACT) program, a new care model for patients to improve quality, outcomes, and experiences of the care provided to AKI survivors afer discharge from the hospital.

Approach: The research team is conducting a pilot feasibility clinical trial to determine the feasibility and acceptability of the ACT program and the preliminary eficacy of ACT on clinical and patient-reported outcomes. Outcomes include hospital readmissions, recurrent episodes of AKI, and kidney function afer discharge, as well as quality of life. The intervention uses electronic indicators to identify AKI survivors, then connects them with nurse educators and care coordinators prior to discharge from the hospital, and a follow-up visit with a clinician and pharmacist within 14 days afer discharge. Feasibility and acceptability are assessed with mixed methods to evaluate the perspectives of patients and clinicians.

Results: Early results published from this study show that patients and clinicians find the ACT intervention to be feasible and scalable, and that it addresses gaps in care for AKI survivors. Multidisciplinary care teams are able to extend the capacity for monitoring kidney health among AKI survivors.^1,2^ Findings on the program’s impact on clinical and patient-reported outcomes are forthcoming and can be found here (https://reporter.nih.gov/search/B59UQqJZJkyq8uJT-klgLg/project-details/10395486#details).

#### Primary Care Relevance

In a primary care setting, these data could assist clinicians with providing more high-quality, well-coordinated, and patient-centered care for survivors of AKI. The multidisciplinary approach which involves nurses and pharmacists alongside physicians and advanced practice providers appears feasible and is an attractive way to leverage the expertise of the entire care team.^3^

#### AHRQ Primary Care Priority Area

Research on management of clinical areas unique to primary care, such as multiple chronic conditions, preventive care, undiferentiated syndromes, or behavioral and mental healthcare that is integrated within primary care.

1 Barreto EF, Schreier DJ, May HP, Mara KC, Chamberlain AM, Kashani KB, . Incidence of Serum Creatinine Monitoring and Outpatient Visit Follow-Up among Acute Kidney Injury Survivors afer Discharge: A Population-Based Cohort Study. Am J Nephrol. 2021;52(10–11):817–26.34727542

2 Schreier DJ, Rule AD, Kashani KB, Mara KC, Kane-Gill SL, Lieske JC, . Nephrotoxin Exposure in the 3 Years following Hospital Discharge Predicts Development or Worsening of Chronic Kidney Disease among Acute Kidney Injury Survivors. Am J Nephrol. 2022;53(4):273–81.35294951

3 Barreto EF, May HP, Schreier DJ, Meade LA, Anderson BK, Rensing ME, Ruud KL, Kattah AG, Rule AD, McCoy RG, Finnie DM, Herges JR, Kashani KB; ACT Study Group. Development and Feasibility of a Multidisciplinary Approach to AKI Survivorship in Care Transitions: Research Letter. Can J Kidney Health Dis. 2022 Mar 6;9:20543581221081258. doi: 10.1177/20543581221081258. PMID: 35284082; PMCID: PMC8905052.35284082

### P2 Using an Electronic Screening Tool to Identify Adolescents at Risk for STIs

This study aims to adapt an electronic sexually transmitted infections (STIs) risk assessment tool for implementation during pediatric primary care visits.

Portrait of Fahd Ahmad, MD, MSCI

PI Name: Fahd Ahmad, MD, MSCI

Grant Title: Implementation of Electronic Health Screening in Primary Care to Improve STI Testing (https://reporter.nih.gov/project-details/10018013)

Organization Name: Washington University

Organization Type; Department: School of Medicine; Pediatrics

Grant Type: R18 (Research Demonstration and Dissemination Project)

Grant Period: 09/30/2019 – 09/30/2023

Topic Areas: Practice and Quality Improvement, Digital Healthcare, Women’s Health/Reproductive Health

#### Study Overview

Problem: Adolescents have high rates of STIs, including gonorrhea, chlamydia, and HIV. Unfortunately, they ofen do not receive STI screening during pediatric primary care visits, increasing the risk of undiagnosed STIs. This leads both to significant spread in the population and avoidable medical complications.

Main Objective: To identify adolescents at risk for STIs and provide testing by implementing electronic STI risk assessment in pediatric primary care settings.

Approach: This study will implement a STI risk assessment tool in three pediatric primary care clinics in the St. Louis metropolitan area, which has a high incidence of STIs. The assessment tool, which was initially developed for use in the emergency department, is completed by the patient and includes a branch-logic questionnaire along with a clinical decision support tool. Once completed, the patient’s responses and STI testing recommendations are integrated into the electronic health record, allowing the clinical team to easily identify patients at risk for STIs and arrange for testing and follow-up.

For this study, the research team is:

- Adapting the electronic STI risk assessment tool and clinical workflows to support successful implementation in pediatric clinics;
- Implementing use of the tool in three pediatric clinics; and
- Assessing changes in STI testing and treatment in the three pediatric clinics afer implementation.

Results: Identified barriers to STI screening and testing adolescents included clinicians’ perception of STI risk, time constraints during visits, and lack of clinic capacity to conduct testing.^1^ In initial testing of the electronic risk assessment tool, the research team found that primary care physicians and clinical staf as well as adolescents liked the tool and found it easy to use.^2^ Qualitative interviews revealed that physicians and clinic staf thought the tool would fit well into their existing primary care workflows.^2^ Patients, physicians, and clinical staf also believed the private nature of the tool would help adolescents share sensitive information with their physician, particularly when a parent is present.^2^

Additional findings are forthcoming. Publications can be found here (https://reporter.nih.gov/project-details/10018013).

#### Primary Care Relevance

Adapting an electronic STI risk assessment tool for use in a primary care setting has the potential to significantly improve STI care for adolescents.

#### AHRQ Primary Care Priority Area

Research to improve primary care, including regarding quality, access and afordability, the workforce, care delivery models, financing, digital healthcare, person-centeredness, and health equity.

1 Ahmad FA, Dickey V, Tetteh EK, Foraker R, McKay VR. The Use of the Consolidated Framework for Implementation Research to Understand Facilitators and Barriers to Sexually Transmitted Infection Screening in Primary Care. Sex Transm Dis. 2022 Sep 1;49(9):610–615. doi: 10.1097/OLQ.0000000000001656. Epub 2022 Jun 2. PMID: 35649512.35649512

2 Ahmad FA, Chan P, McGovern C, Dickey V, Foraker R, McKay V. Adapting an Electronic STI Risk Assessment Program for Use in Pediatric Primary Care. J Prim Care Community Health. 2023 Jan–Dec;14:21501319231172900. doi: 10.1177/21501319231172900. PMID: 37199386; PMCID: PMC10201180.37199386

### P3 Using Veterans Health Administration Data to Understand How Primary Care Team Configuration and Stability Impact Quality

This study uses a large, diverse national sample of primary care teams to examine the impact of diferent team configurations.

Portrait of Sylvia J. Hysong, PhD

PI Name: Sylvia J. Hysong, PhD

Grant Title: Impact of Team Configuration and Team Stability on Primary Care Quality (https://reporter.nih.gov/project-details/10146331)

Organization Name: Baylor College of Medicine

Organization Type; Department: School of Medicine, Internal Medicine

Grant Type: R01 (Research Project)

Grant Period: 07/6/2018 – 4/30/2023

Topic Areas: Practice and Quality Improvement, Healthcare Systems/Infrastructure

#### Study Overview

Problem: Although the efectiveness of primary care teams is well documented, the impact of diferent types of care team configurations on the quality of care is not well understood.

Main Objective: To examine the relationship between the configuration of the primary care team and the stability of the care provided.

Approach: The research team used a large, national dataset from the Veterans Health Administration (VHA) to study the efectiveness of diferent primary care team configurations. First, the research team convened a panel of experts to select and prioritize a set of primary care performance measures. The panel reviewed existing performance measures and drew upon evidence-based methodology from organizational psychology normally used for developing performance measurement systems (Productivity Measurement and Enhancement System, or ProMES) to select a curated set of metrics that represented high quality primary care. The panel selected sixteen performance indicators encompassing three fundamental dimensions of primary care: access, patient-health care team partnerships, and technical quality. The research team used a subset of these indicators as the outcomes of the study.

Next, the research team built a dataset with measures of clinical performance, team configuration, and team and role stability for a sample of nearly 6,000 primary care teams from more than 1,000 VHA healthcare centers nationwide. The researchers computed team configurations for each team using network analysis. The researchers then used hierarchical linear models to test the relationship between clinical performance measures and adherence to recommended team configurations, team stability, and the stability of team leadership over time.

Results: In preliminary findings, the research team found that diferent team characteristics were associated with diferent quality and access outcomes. In most cases, teams with more full-time equivalent personnel appeared to have better outcomes. In addition, teams with high levels of churn in the nursing role – where the nurse role is always filled, though by diferent nurses over time – tended to have worse outcomes. The team used these findings to assemble a Primary Care Team-Based Care Toolkit to help primary care teams work more efectively.

Final results and publications from this study are forthcoming and will be posted here (https://reporter.nih.gov/project-details/10146331).

#### Primary Care Relevance

This study aims to develop clear guidance on the best primary care team configurations for efectively providing high-quality and patient-centered care.

#### AHRQ Primary Care Priority Area

Research to improve primary care, including regarding quality, access and afordability, the workforce, care delivery models, financing, digital healthcare, person-centeredness, and health equity.

### P4 Impacts of Changes in Payment Policy on Access to Primary Care for People with Lower Incomes

This study examines the impact of primary care provider payment policy on outpatient care, clinical events, and medical spending.

Portrait of Vicki Fung, PhD

PI Name: Vicki Fung, PhD

Grant Title: Medicaid Payment Policy and Access to Care for Dual Eligible Beneficiaries (https://reporter.nih.gov/project-details/9993514)

Organization Name: Massachusetts General Hospital

Grant Type: R01 (Research Project)

Grant Period: 09/01/2016 - 08/31/2023

Topic Areas: Healthcare Systems/ Infrastructure, Health Equity

#### Study Overview

Problem: People who are eligible for both Medicare and Medicaid, referred to as “dually eligible beneficiaries,” are a medically vulnerable population with high medical care costs. Dually eligible beneficiaries also ofen have inadequate access to high quality care.

Main Objective: To identify the efects of the temporary Afordable Care Act increases in Medicaid payment rates for primary care providers in 2013 and 2014, which increased payment rates for dually eligible beneficiaries by up to 25%.

Approach: The research team is using Medicare claims data to compare primary care visit rates for beneficiaries who were eligible for increased primary care payments to a control group of Medicare beneficiaries with lower incomes in the same geographical area who were not eligible for increased payments. The team is also examining diferences in the proportion of primary care providers’ Medicare patients who are dually eligible before and afer the policy change in States with temporary or extended fee bumps (i.e., States that continued payment increases afer 2014) versus minimal change in payments.

Results: To date, findings from this study show that relative rates of primary care visits for dually eligible beneficiaries did not increase overall during the years with a reimbursement increase compared with the control group, although there was wide variation across States. In addition, primary care providers’ caseloads of dually eligible beneficiaries declined between 2011 and 2017 and were not consistently associated with the payment change.^1^ These findings indicate that administrative and implementation barriers may have limited the efects of the reimbursement increase.^2^ Additional publications for this study are expected. Current and future publications can be found here (https://reporter.nih.gov/project-details/9993514).

#### Primary Care Relevance

Findings from this study can help policymakers consider how to best improve primary care access and utilization for Medicare beneficiaries with lower incomes.

#### AHRQ Primary Care Priority Area

Research to improve primary care, including regarding quality, access and afordability, the workforce, care delivery models, financing, digital healthcare, person-centeredness, and health equity.

1 Fung, V., McCarthy, S., Price, M., Hull, P., Lê Cook, B., Hsu, J., & Newhouse, J. P. (2021). Payment discrepancies and access to primary care physicians for dual-eligible Medicare-Medicaid beneficiaries. Medical care, 59(6), 487.33973937

2 Fung, V., Price, M., Hull, P., Lê Cook, B., Hsu, J., & Newhouse, J. P. (2021). Assessment of the patient protection and afordable care act’s increase in fees for primary care and access to care for dual-eligible beneficiaries. JAMA network open, 4(1), e2033424–e2033424.33475756

### P5 Assessing the Impact of the Affordable Care Act on Reproductive Health Care

This study examines the impact of the Afordable Care Act and Medicaid expansion on the reproductive health care provided in community health centers.

Portrait of Erika L. Barth Cottrell, PhD, MPP

PI Name: Erika L. Barth Cottrell, PhD, MPP

Grant Title: Reproductive care in the safety net: Women’s health afer Afordable Care Act implementation (EVERYWOMAN) (https://reporter.nih.gov/project-details/10148802)

Organization Name: OCHIN, INC

Grant Type: R01 (Research Project)

Grant Period: 08/01/2017 – 09/30/2022

Topic Areas: Health Equity; Women’s Health/ Reproductive Health

#### Study Overview

Problem: Reproductive health is a central component of preventive care. Despite the evidence of its importance and efectiveness, there are well-documented disparities in access to and utilization of reproductive health care services, especially among racial and ethnic minorities and people with lower incomes. The Afordable Care Act (ACA) sought to increase access to vital reproductive care services through the expansion of Medicaid coverage. However, only 31 States voluntarily expanded Medicaid, and the impact of expansion on reproductive services is not well understood.

Main Objective: 1) To use the natural experiment of Medicaid expansion in some States but not others, to better understand the impact of the ACA on access to comprehensive preventive, contraceptive, and pregnancy-related care; and 2) To examine the essential role community health centers in the US play in connecting women to quality reproductive health care.

Approach: The study uses electronic health record (EHR) data from the ADVANCE clinical data research network (CDRN) and community data. The research team uses patient-level data for over 3 million patients to examine the provision and utilization of reproductive services before and afer Medicaid expansion, and between expansion and non-expansion states. The team also uses EHR data to identify the individual, clinic, and state-level factors associated with reproductive health care. In addition, the research team collects qualitative data to understand patient and provider perspectives on access to reproductive care in community health centers.

Results: The research team found that five out of six key preventive care services (screening for HIV, cervical cancer, and chlamydia; and vaccination for HPV and influenza) increased at community health centers in both expansion and non-expansion states afer the expansion of Medicaid, but remain low across the board.^1^ The research team also found that community health centers play an important role in providing the most efective contraceptive methods for women with lower incomes.^2^ These and additional publications from the grant are posted here (https://reporter.nih.gov/project-details/10148802).

#### Primary Care Relevance

Findings from this study show that the policies that fund health centers and expand coverage for reproductive health services in primary care settings are efective ways to ensure ongoing access to equitable reproductive health care.

#### AHRQ Primary Care Priority Area

Research to improve primary care, including regarding quality, access and afordability, the workforce, care delivery models, financing, digital healthcare, person-centeredness, and health equity.

1 Hatch, B., Hoopes, M., Darney, B.G., Marino, M., Templeton, A.R., Schmidt, T., Cottrell, E. (2021). Impacts of the afordable care act on receipt of women’s preventive services in community health centers in medicaid expansion and nonexpansion states. Womens Health Issues. 31(1):9–16. doi: 10.1016/j.whi.2020.08.011.33023807

2 Darney B.G., Biel F.M., Oakley J., Rodriguez M.I., Cottrell, E.K. (2022). US “safety net” clinics provide access to efective contraception for adolescents and young women, 2017-2019. American Journal of Public Health. 112(S5):S555–S562. doi: 10.2105/AJPH.2022.306913.35767786

### P6 Understanding the Combined Impact of Healthcare Delivery and Payment Reform Models

This study examines the combined impact of primary care organization participation in multiple healthcare delivery and payment reform models on care quality and value.

Portrait of Julia Adler-Milstein, PhD

PI Name: Julia Adler-Milstein, PhD

Grant Title: Synergies and Sequencing in Delivery and Payment Reform: Understanding What Works (https://reporter.nih.gov/project-details/10233948)

Organization Name: University of California, San Francisco

Organization Type; Department: School of Medicine, Internal Medicine

Grant Type: R01 (Research Project)

Grant Period: 09/01/2017 – 08/31/2023

Topic Areas: Healthcare Systems/ Infrastructure

#### Study Overview

Problem: Multiple delivery and payment reform eforts seek to reduce healthcare costs and improve quality in the U.S. The impacts of these voluntary programs, including Medicare and Medicaid Electronic Health Record Incentive Programs (known as “Meaningful Use”), Patient-Centered Medical Home (PCMH) programs, and Accountable Care Organizations (ACOs), have each been studied. However, little is known about the cumulative impact of the participation by primary care organizations in multiple programs.

Main Objective: To better understand the patterns of participation by primary care organizations in care delivery and payment reform models, and the impact of participation in a combination of programs on care quality and value.

Approach: In this longitudinal observational study, the research team combined secondary datasets to examine the participation of primary care practices in Meaningful Use, PCMH, and/or ACO programs from 2009-2017, and looked at practice characteristics related to participation. The research team is also using Medicare claims data to assess the impact of model participation on the patient outcomes expected to improve under these programs, such as adherence to evidence-based care, reductions in avoidable hospitalizations, and reductions in spending.

Results: Out of over 56,000 primary care organizations in the study, 50% participated in one delivery or payment reform program over the study period, 13% participated in two programs; and 1% participated in all three.^1^ Primary care organizations that are larger, have more primary care providers, have younger providers, and those with more Medicare patients are more likely to participate in more than one program.^1^ In addition, participation in more than one program did not seem to provide synergistic benefits: combined participation in the three programs was associated with small increases in adherence to diabetes guidelines and lower spending on acute care, but participation in single programs was associated with similar benefits.^2^ The researchers suggest that greater synergistic impacts may be possible if future healthcare reform programs have better aligned requirements and goals.

Publications can be found here (https://reporter.nih.gov/project-details/10233948).

#### Primary Care Relevance

This research helps to better understand the impact of multiple delivery and payment reform eforts on primary care. Results can help guide the design and alignment of future policy eforts to improve healthcare quality and reduce costs.

#### AHRQ Primary Care Priority Area

Research to improve primary care, including regarding quality, access and afordability, the workforce, care delivery models, financing, digital healthcare, person-centeredness, and health equity.

1 Adler-Milstein, J., Linden, A., Bernstein, S., Hollingsworth, J., & Ryan, A. (2022). Longitudinal participation in delivery and payment reform programs among US Primary Care Organizations. Health services research, 57(1), 47–55. 10.1111/1475-6773.13646.33644870

2 Adler-Milstein, J., Linden, A., Hollingsworth, J. M., & Ryan, A. M. (2022). Association of primary care engagement in value-based reform programs with health services outcomes: participation and synergies. JAMA Health Forum, 3(2), e220005. 10.1001/jamahealthforum.2022.0005.35977280

### P7 Understanding the Relationship Between Proximity and Utilization of Patient-Centered Medical Homes

This study examines the association between where pediatric Medicaid patients in South Carolina live and their use of patient-centered medical homes (PCMHs) instead of hospitals for health care.

Portrait of Nathaniel Bell, PhD

PI Name: Nathaniel Bell, PhD

Grant Title: Efect of the patient-centered medical home on geographic and racial disparities in health care access (https://reporter.nih.gov/project-details/10004638)

Organization Name: University of South Carolina at Columbia

Organization Type: School of Nursing

Grant Type: R03 (Small Research Grant)

Grant Period: 09/01/2019 – 08/31/2022

Topic Areas: Healthcare Systems/ Infrastructure

#### Study Overview

Problem: Patient-centered medical homes (PCMHs) provide primary care using a model designed to put patients at the center of care that is comprehensive, coordinated, accessible, safe, and high-quality. In South Carolina, PCMHs participating in Medicaid Managed Care are available across the State. However, PCMHs are generally concentrated in only four counties, and 10% of the State’s Medicaid population does not have a PCMH in the county where they live. Little is known about how much travel distance impacts the use of PCMHs.

Main Objective: To better understand the impact of where a patient lives on their use of a PCMH instead of a hospital for care.

Approach: The research team used pediatric medical claims data in South Carolina from the years 2016-2018 to identify PCMH enrollment and examine proximity to a PCMH versus a hospital for children with pre-existing ADHD (2,959 Medicaid beneficiaries) and asthma (6,390 Medicaid beneficiaries). Using primary care quality indicators, such as the number of avoidable emergency department encounters, the researchers then examined the relationship between travel distance and utilization rates.

Results: The research team found that low rates of uninsured and low poverty rates are the most consistent indicators of PCMH availability in a county.^1^ Among children in the ADHD cohort enrolled at a PCMH, the researchers found that avoidable emergency department use decreased as proximity to a PCMH improved relative to a hospital.^2^ This evidence suggests that the distance between patients and PCMHs plays a role in PCMH use — at least for pediatric groups with certain pre-existing conditions. This finding may also help to explain disappointing results in prior PCMH research studies that lacked geographic information for patients. Publications from this grant are posted here (https://reporter.nih.gov/project-details/10004638).

#### Primary Care Relevance

This research helps to better understand how travel distance impacts PCMH utilization. Findings could lead to policy reform to establish guidelines to increase access to PCMHs among Medicaid patients.

#### AHRQ Primary Care Priority Area

Research to improve primary care, including regarding quality, access and afordability, the workforce, care delivery models, financing, digital healthcare, person-centeredness, and health equity.

1 Bell N, Wilkerson R, Mayfield-Smith K, Lòpez-De Fede A. Community social determinants and health outcomes drive availability of patient-centered medical homes. Health Place. 2021 Jan;67:102439. doi: 10.1016/j.healthplace.2020.102439. Epub 2020 Nov 16. PMID: 33212394.33212394

2 Bell N, Lòpez-De Fede A, Cai B, Brooks J. Geographic proximity to primary care providers as a risk-assessment criterion for quality performance measures. PLoS One. 2022 Sep 6;17(9):e0273805. doi: 10.1371/journal.pone.0273805. PMID: 36067180; PMCID: PMC9447909.36067180

### P8 Do Telemedicine Visits Provide Similar Quality and Safety as In-Person Visits?

This study helps to build understanding about the quality of care, potential benefits, and the future role of telemedicine in primary care settings.

Portrait of Mary Reed, DrPH

PI Name: Mary Reed, DrPH

Grant Title: Patient choice of telemedicine encounters (https://reporter.nih.gov/project-details/10350592)

Organization Name: Kaiser Foundation Research Institute

Grant Type: R01 (Research Project)

Grant Period: 05/15/2018 - 2/29/2024

Topic Areas: Digital Healthcare, Person-Centered Care, Telehealth

#### Study Overview

Problem: More patients are using telemedicine visits for primary care, which reduces barriers to care such as transportation, childcare, and the need to take time of from work. However, before the COVID-19 pandemic there had been little research comparing the quality and efectiveness of telemedicine to in-person visits.

Main Objective: To understand which patient characteristics are associated with telemedicine utilization, and to understand how telemedicine compares in quality, care processes, and patient outcomes to in-person care.

Approach: To collect information about technology usability, convenience, and patient-reported outcomes for telemedicine visits in primary care, the research team conducted surveys with patients (700 pre-pandemic and 1,000 post pandemic) and interviews with clinicians and organizational leaders. The research team is also using electronic health record data in northern California from the multi-year study period to examine rates of prescribing and ordering, follow-up visits, and emergency department visits following telemedicine preventative care visits compared to in-person visits.

Results: [underlined: Prior to the COVID-19 pandemic], the research team found that patients who were female, under 40, and had access to high-speed internet selected telemedicine visits more ofen.^1^ In addition, Black patients were more likely than patients of other races to choose to have a telemedicine visit.^1^ Researchers also found that there were lower rates of prescribing and higher rates of follow-up ofice visits for patients with telemedicine visits compared to patients with in-person visits, but there were no significant diferences in emergency visits or hospitalizations.^2^

[underlined: During the pandemic], the research team found that Black and Hispanic patients, patients living in neighborhoods with lower internet access, and patients living in neighborhoods with lower socioeconomic status were more likely to schedule telephone visits than video visits.^3^ Patients more likely to schedule video visits included people 65 or older, those with prior experience having video visits, and those visiting their usual primary care provider.^3^ Rates of medication prescriptions and laboratory/imaging orders were higher for patients with video visits compared to patients with telephone visits. Rates of follow-up ofice visits, emergency department visits, and hospitalizations were lower following video visits compared to telephone visits, but these outcomes were rare across all telemedicine visits.^4^

Publications from this study can be found here (https://reporter.nih.gov/project-details/10350592).

#### Primary Care Relevance

Findings from this study demonstrate that while there are some diferences in primary care treatment via telemedicine compared with in-person care, negative outcomes were rare. Use of telemedicine shifed dramatically during the COVID-19 pandemic, with some gaps in equitable use of video telemedicine.

#### AHRQ Primary Care Priority Area

Research to improve primary care, including regarding quality, access and afordability, the workforce, care delivery models, financing, digital healthcare, person-centeredness, and health equity.

1 Reed ME, Huang J, Graetz I, Lee C, Muelly E, Kennedy C, Kim E. Patient Characteristics Associated With Choosing a Telemedicine Visit vs Ofice Visit With the Same Primary Care Clinicians. JAMA Netw Open. 2020 Jun 1;3(6):e205873. doi: 10.1001/jamanetworkopen.2020.5873. PMID: 32585018; PMCID: PMC7301227.32585018

2 Reed M, Huang J, Graetz I, Muelly E, Millman A, Lee C. Treatment and Follow-up Care Associated With Patient-Scheduled Primary Care Telemedicine and In-Person Visits in a Large Integrated Health System. JAMA Netw Open. 2021 Nov 1;4(11): e2132793. doi: 10.1001/jamanetworkopen.2021.32793. PMID: 34783828; PMCID: PMC8596201.34783828

3 Huang J, Graetz I, Millman A, Gopalan A, Lee C, Muelly E, Reed ME. Primary care telemedicine during the COVID-19 pandemic: patient’s choice of video versus telephone visit. JAMIA Open. 2022 Jan 19;5(1):ooac002. doi: 10.1093/jamiaopen/ooac002. PMID: 35146380; PMCID: PMC8822408.35146380

4 Huang J, Gopalan A, Muelly E, Hsueh L, Millman A, Graetz I, Reed M. Primary care video and telephone telemedicine during the COVID-19 pandemic: treatment and follow-up health care utilization. Am J Manag Care. 2023 Jan 1;29(1):e13–e17. doi: 10.37765/ajmc.2023.89307. PMID: 36716159.36716159

### P9 Using a Mobile Health Tool to Improve Patient-Centered Care for Patients with Type 2 Diabetes

This study tests a mobile health tool for collecting and sharing patient-reported outcomes as a part of everyday clinical practice, and ultimately, whether the tool improves care and outcomes for individuals with type 2 diabetes.

Portrait of Antoinette M. Schoenthaler, EdD

PI Name: Antoinette M. Schoenthaler, EdD

Grant Title: i-Matter: Investigating an mHealth texting tool for embedding patient-reported data into diabetes management (https://reporter.nih.gov/project-details/10431814)

Organization Name: New York University Grossman School of Medicine

Organization Type: School of Medicine; Internal Medicine

Grant Type: R01 (Research Project)

Grant Period: 09/01/2018 – 06/30/2024

Topic Areas: Person-Centered Care, Digital Healthcare, Practice and Quality Improvement

#### Study Overview

Problem: Much of clinical practice for type 2 diabetes focuses on addressing the impacts of the disease on a patient’s physical health. Inclusion of the patients’ perspective of their health and functional status and understanding what outcomes they most desire is less common, but necessary for improving care.

Main Objective: To evaluate the usability and eficacy of a mobile health tool that incorporates patients’ perspective into the clinical management of type 2 diabetes.

Approach: This study will implement an innovative mobile health tool for managing diabetes care (i-Matter). The tool uses text-messaging to collect and share patient-reported outcomes and sends patients feedback and motivational messages based on the information they share. The platform also creates dynamic data visualizations of the patient’s data, which is integrated into the electronic health record, and can be reviewed by their primary care clinicians during and between visits.

In the first phase of the study, the research team will use qualitative methods to evaluate the usability, performance, and workflow integration of the i-Matter tool in meeting the needs of clinicians and patients. In the second phase, the research team will randomize 282 participants to receive either usual care for diabetes or care supplemented with the i-Matter tool. Outcomes include mean reduction in blood sugar levels, changes in patient adherence to lifestyle and medication recommendations, and patient-provider communication.

Results: While the study is ongoing, the research team has published results from an analysis on longitudinal user engagement data. Analyses revealed three distinct subgroups of patients used the i-Matter tool: a low-engaged group, a moderately engaged group, and a highly engaged group, with the latter being the largest.^1^ Future analyses will determine whether these engagement patterns impact patients’ behavioral and clinical health outcomes. If so, engagement patterns can be used to identify patients in need of additional support.

Current and future publications from this grant will be posted here (https://reporter.nih.gov/project-details/10431814).

#### Primary Care Relevance

This project has the potential to harness the use of technology, such as the mobile phone and electronic health record, to support the delivery of high-quality patient-centered care for patients with type 2 diabetes in primary care settings.

#### AHRQ Primary Care Priority Area

Harnessing data and technology to conduct research on characteristics of primary care that may influence patient outcomes, such as whole person care, care coordination, continuity of care, and comprehensiveness of care.

1 Mandal, S., Belli, H. M., Cruz, J., Mann, D., & Schoenthaler, A. (2022). Analyzing user engagement within a patient-reported outcomes texting tool for diabetes management: engagement phenotype study. JMIR Diabetes, 7(4), e41140. 10.2196/41140.36374531

### P10 Improving Clinical-Community Linkages in Primary Care for Patients with Multiple Chronic Conditions

This study tests an innovative model for including primary care clinicians in systems to connect patients with multiple chronic conditions to needed community resources.

Portrait of Alexander H Krist; MD, MPH

PI Name: Alexander H Krist; MD, MPH

Grant Title: Enhanced Care Planning and Clinical-Community Linkages to Comprehensively Address the Basic Needs of Patients with Multiple Chronic Conditions (https://reporter.nih.gov/project-details/10335134)

Organization Name: Virginia Commonwealth University

Organization Type; Department: School of Medicine; Family Medicine

Grant Type: R01 (Research Project)

Grant Period: 03/05/2019 - 02/01/2024

Topic Areas: Person-Centered Care, Public Health and Community Integration, Practice and Quality Improvement, Multiple Chronic Conditions

#### Study Overview

Problem: Medical care to manage multiple chronic conditions (MCC) is unlikely to be efective for patients who are struggling to meet their basic needs, such as having stable housing and enough to eat.

Main Objective: To examine how primary care clinicians can participate in new models for connecting patients with needed community services, and measure whether doing so improves patient outcomes.

Approach: In In this clinician-level randomized controlled trial, 60 clinicians from the Virginia Ambulatory Care Outcomes Research Network (ACORN) were randomized to provide either usual care (the control group) or enhanced care planning with clinical-community linkage support (the intervention group) for 600 patients with uncontrolled MCC. In the intervention group, patients were first screened for health behavior, mental health, and social needs using an enhanced care planning tool. Then, clinical navigators helped patients prioritize their needs and create care plans to help guide the care team. Next, clinical navigators and community health workers worked to connect patients with needed resources in the community. Six months and two years afer enrollment, the research team assessed MCC health outcomes and patient-reported physical health, mental health, and social wellbeing outcomes. The research team also conducted medical record reviews, patient surveys, field observations, and semi-structured interviews with patients, clinicians, and community stakeholders to understand how contextual influences impacted the implementation and efectiveness of the intervention.

Results: The research team has learned that patient navigation services do not require a large time commitment or intensive training. However, due to current demands on primary care teams, most practices require additional staf or resources to be able to provide these services.^1^ Patients report being less comfortable discussing social needs that are not health-related with their primary care team, such as finances, housing, and transportation. Yet, they are willing to discuss their needs when a strong relationship with the clinician already exists, there is adequate time provided for this discussion, and the practice ensures referrals to helpful community services.^2^

Additional results from this study are forthcoming. Publications from this grant will be posted here (https://reporter.nih.gov/project-details/10335134).

#### Primary Care Relevance

This study helps to inform eforts to include primary care clinicians in the growing number of Accountable Health Care-like systems as a strategy to address mental health and social needs.

#### AHRQ Primary Care Priority Area

Research to improve primary care, including regarding quality, access and afordability, the workforce, care delivery models, financing, digital healthcare, person-centeredness, and health equity.

1 Hinesley JLG, Brooks EM, O’Loughlin K, Webel B, Britz J, Kashiri PL, Scheer J, Richards A, Lavallee M, Sabo RT, Huebschmann AG, Krist AH. Feasibility of Patient Navigation for Care Planning in Primary Care. J Prim Care Community Health. 2022 Jan–Dec;13:21501319221134754. doi: 10.1177/21501319221134754. PMID: 36348571; PMCID: PMC9647277.36348571

2 O’Loughlin K, Shadowen HM, Haley AD, Gilbert J, Lail Kashiri P, Webel B, Huebschmann AG, Krist AH. Patient Preferences for Discussing and Acting on Health-Related Needs in Primary Care. J Prim Care Community Health. 2022 Jan–Dec; 13:21501319221115946. doi: 10.1177/21501319221115946. PMID: 35920033; PMCID: PMC9358340.35920033

### P11 Identifying Ways to Improve Preventive Care for Children

This study examines parental and child level information to identify ways to improve rates of preventive care, including vaccinations, for children.

Portrait of Jennifer DeVoe, MD, DPhil

PI Name: Jennifer DeVoe, MD, DPhil

Grant Title: Helping gEnerations Identify Risks (Heirs) to Health (https://reporter.nih.gov/project-details/10141231)

Organization Name: Oregon Health & Science University

Organization Type; Department: School of Medicine; Family Medicine

Grant Type: R01 (Research Project)

Grant Period: 07/01/2019-04/30/2023

Topic Areas: Person Centered Care, Health Equity

#### Study Overview

Problem: Many children are not receiving adequate preventive healthcare. This includes missing yearly well-child visits, and not being up-to-date on recommended vaccinations, screenings, and assessments.

Main Objective: To identify which parental factors are most strongly associated with children receiving recommended preventive care and explore how social determinants of health influence healthcare utilization for the whole family.

Approach: The research team conducted qualitative interviews with approximately 30-40 parents to understand their perceptions towards preventive care and learn what barriers could be addressed to make it easier for their children to receive recommended care. Using electronic health record data from over 2 million patients, including over 350,000 children from 18 states, the researchers analyzed health, healthcare factors, and social determinants of health for both parents and children. The research team used a sequential mixed-methods approach to conduct analyses based on qualitative insights.

Results: To date, findings from this study show that parents who participate in preventive care themselves are more likely to bring their children in for routine well-child visits.^1^ In addition, children are more likely to be up-to-date on routine vaccinations if their parents receive regular vaccinations.^2^ Additional publications for this study are expected. Current and future publications can be found here (https://reporter.nih.gov/project-details/10141231).

#### Primary Care Relevance

Findings from this study help inform potential primary care interventions to improve the access and utilization of children’s recommended healthcare by improving the preventive healthcare for parents.

#### AHRQ Primary Care Priority Area

Research to improve primary care, including regarding quality, access and afordability, the workforce, care delivery models, financing, digital healthcare, person-centeredness, and health equity.

1 Angier, H., Kaufmann, J., Heintzman, J., O’Malley, J., Moreno, L., Giebultowicz, S., & Marino, M. (2022). Association of Parent Preventive Care with their Child’s Recommended Well-Child Visits. Academic Pediatrics, 22(8), 1422–1428.35378334

2 Kaufmann, J., DeVoe, J. E., Angier, H., Moreno, L., Cahen, V., & Marino, M. (2022). Association of parent influenza vaccination and early childhood vaccinations using linked electronic health record data. Vaccine, 40(49), 7097–7107.36404427

### P12 Using a Televideo-based Training Model for Providers to Expand Treatment for Opioid Use Disorder in Rural New Mexico

This study examined the feasibility of using the Extensions for Community Healthcare Outcomes (ECHO^©^) model to train primary care providers in rural New Mexico to provide medications for opioid use disorders (MOUD).

Portrait of Julie G Salvador, PhD

PI Name: Julie G Salvador, PhD

Grant Title: ECHO-F Model to Expand Medication Assisted Treatment in Rural Primary Care (https://reporter.nih.gov/project-details/10221050)

Organization Name: University of New Mexico Health Sciences Center

Organization Type; Department: School of Medicine; Psychiatry

Grant Type: R18 (Research Demonstration and Dissemination Project)

Grant Period: 08/01/2017 - 01/31/2023

Topic Areas: Behavioral Health and Substance Use Disorders, Digital Healthcare, Telehealth, Opioids

#### Study Overview

Problem: Opioid use is the main driver of overdose deaths – which are increasing at an alarming rate across the country. Efective treatment of opioid use disorder in New Mexico is hampered by severe shortages in the primary care workforce and by how much of the State is rural. The ECHO^©^ model has been used to build clinician capacity for implementing best practices for a range of health conditions, but its use for expanding access to behavioral health is less well explored.

Main Objective: To use the ECHO^©^ model, with additional supports as needed, to train primary care providers in rural New Mexico to provide MOUD for patients with opioid use disorder.

Approach: Using the ECHO^©^ model, the research team aimed to train 240 providers (plus additional clinic staf) in 80 clinics on how to implement MOUD.^1^ The ECHO^©^ model is a televideo-based strategy for remotely training health care providers using both didactic and problem-based learning. MOUD is an evidence-based approach that uses medication combined with psychosocial and community-based supports to treat opioid use disorder. The research team monitored participating providers’ implementation benchmarks, and provided support as necessary for providers who were not able to reach benchmarks. Inferential analysis was used to understand the feasibility of accomplishing implementation benchmarks and logistic regression analyses were conducted to assess the relationship between participation and dichotomous achievement measures.

Results: To date, published results from this study have shown positive feedback from clinicians on the ECHO^©^ MOUD curriculum, but varying rates of participation in sessions. Consistently reported barriers to attending trainings were provider’s clinical duties and lack of time to participate.^1,2^ The study has also found that attending more ECHO^©^ MOUD sessions is associated with clinicians making more progress towards providing MOUD (such as completing the required training and paperwork), starting to prescribe buprenorphine to treat opioid use disorder, and adding more patients onto buprenorphine treatment.^3^ Findings regarding the efectiveness of the program for patients are forthcoming. Publications can be found here (https://reporter.nih.gov/project-details/10221050).

#### Primary Care Relevance

Findings from this grant inform the feasibility of using the ECHO^©^ model to expand access to medications for opioid use disorders through primary care in rural and high need/low resource settings.

#### AHRQ Primary Care Priority Area

Harnessing data and technology to conduct research on characteristics of primary care that may influence patient outcomes, such as whole person care, care coordination, continuity of care, and comprehensiveness of care.

1 Salvador JG, Bhatt SR, Jacobsohn VC, Maley LA, Alkhafaji RS, Rishel Brakey H, Myers OB, Sussman AL. Feasibility and acceptability of an online ECHO intervention to expand access to medications for treatment of opioid use disorder, psychosocial treatments and sOupports. Subst Abus. 2021;42(4):610–617. doi: 10.1080/08897077.2020.1806184. Epub 2020 Aug 19. PMID: 32814005; PMCID: PMC8552422.32814005

2 Salvador J, Bhatt S, Fowler R, Ritz J, James R, Jacobsohn V, Brakey HR, Sussman AL. Engagement With Project ECHO to Increase Medication-Assisted Treatment in Rural Primary Care. Psychiatr Serv. 2019 Dec 1;70(12):1157–1160. doi: 10.1176/appi.ps.201900142. Epub 2019 Aug 22. PMID: 31434561; PMCID: PMC8552451.31434561

3 Salvador J, Rishel Brakey H, Alkhafaji RS, Fuentes J, McWethy M, Rombach L, Abeyta R, Martinez J, Sussman A, Myers O. Participation in ECHO is Associated with Expanding Buprenorphine Treatment in Rural Primary Care for Patients with Opioid Use Disorder. Poster session presented at NAPCRG Annual Meeting; November 2022; Phoenix, Arizona.

### P13 Developing a Prediction Model to Identify Health Clinics at High-Risk for Clinician Burnout

This study develops and validates a model to identify health clinics at high-risk for clinician burnout, which could inform practice improvement eforts to prevent burnout before it occurs.

Portrait of Daniel Tawfik, MD, MS

PI Name: Daniel Tawfik, MD, MS

Grant Title: Development and Validation of a Prediction Model to Address Physician Burnout (https://reporter.nih.gov/project-details/10252902)

Organization: Stanford University

Grant Type: K08 (Mentored Clinical Scientist Development Award)

Grant Period: 09/30/2020-09/29/2025

Topic Areas: Primary Care Workforce, Digital Healthcare, Patient Safety

#### Study Overview

Problem: Over 500,000 physicians in the United States experience symptoms of burnout at any given time. In addition to the impacts on afected clinicians, burnout also negatively afects quality of care and patient safety. Unfortunately, there is currently no reliable method to proactively identify high-risk clinics and intervene before burnout occurs.

Main Objective: To develop and validate a prediction model that uses existing operational data to identify clinics at high-risk for clinician burnout.

Approach: Researchers are creating a database with practice-specific metrics from Stanford primary care clinics, including electronic health record (EHR) usage measures. Using a machine learning approach, the research team will use the data to develop a model to quantify the risk for clinician burnout and identify clinics at high risk. The research team will then conduct a qualitative assessment to refine the prediction model and then seek to demonstrate the model’s predictive validity at the clinic level based on routinely administered surveys measuring clinician burnout.

Results: To date, researchers have identified two practice-specific operational domains that relate to wellbeing and risk of burnout that could be quantified in a machine learning model alongside EHR measures. The first factor is the efect of people leaders – when leaders are available at expected times, and feedback is efective, predictable, and respectful, employees are more likely to feel a sense of psychological safety and are less likely to feel emotional exhaustion and burnout.^1^ Second, healthcare workers who are more likely to be at high-risk for burnout include women physicians, midcareer physicians, healthcare workers with adult children, and healthcare workers working less than full-time.^2^ Additional study findings are forthcoming. Current and future publications can be found here (https://reporter.nih.gov/project-details/10252902).

#### Primary Care Relevance

This project has the potential to develop and implement a model that can predict which primary care clinics are at high-risk of burnout before it negatively afects clinicians and patients. This will allow burnout interventions to be tailored to the specific needs of the clinics. Additionally, with a better understanding of which clinic factors impact burnout, leaders can work to proactively make system-level changes to support clinician well-being.

#### AHRQ Primary Care Priority Area

Research to improve primary care, including regarding quality, access and afordability, the workforce, care delivery models, financing, digital healthcare, person-centeredness, and health equity.

1 Tawfik, D. S., Adair, K. C., Palassof, S., Sexton, J. B., Levoy, E., Frankel, A., Leonard, M., Proulx, J., & Profit, J. (2023). Leadership behavior associations with domains of safety culture, engagement, and health care worker well-being. Joint Commission Journal on Quality and Patient Safety, 49(3), 156–165. 10.1016/j.jcjq.2022.12.006.36658090

2 Tawfik, D. S., Shanafelt, T. D., Dyrbye, L. N., Sinsky, C. A., West, C. P., Davis, A. S., Su, F., Adair, K. C., Trockel, M. T., Profit, J., & Sexton, J. B. (2021). Personal and professional factors associated with work-life integration among US physicians. JAMA Network Open, 4(5), e2111575. 10.1001/jamanetworkopen.2021.11575.34042994

### P14 Is Telehealth Effective for Providing Nurse-Led Healthcare to Vulnerable Populations in Colorado?

This study examined the impact of the shif in healthcare to telehealth, as a response to the COVID-19 pandemic, on innovative nurse-led care models used to provide care throughout Colorado.

Portrait of Amy Barton PhD, RN, FAAN, ANEF

PI Name: Amy Barton PhD, RN, FAAN, ANEF

Grant Title: Quality, Safety, Value: Impact of sudden shif to telehealth due to COVID-19 within Nurse-led care models located in Colorado rural and urban communities (https://reporter.nih.gov/project-details/10321967)

Organization Name: University of Colorado Denver

Organization Type: School of Nursing

Grant Type: R01 (Research Project)

Grant Period: 01/01/2021-12/31/2022

Topic Areas: Digital Healthcare, Healthcare Systems/Infrastructure

#### Study Overview

Problem: Due to the public health emergency from the COVID-19 pandemic, there was a sudden shif to using telehealth to provide healthcare. In Colorado, nurse-led models of care are used to deliver behavioral health, primary care, prenatal care, and home visitation to rural and economically vulnerable populations. The impacts of the abrupt and unexpected shif to telehealth on nurse-led models of care are unknown.

Main Objective: To evaluate the impacts of the sudden shif to telehealth at the onset of the COVID-19 pandemic on nurse-led care for vulnerable patients across Colorado.

Approach: The research team of nurse scientists used claims data, surveys, and interviews in a mixed methods approach to evaluate telehealth implementation on statewide utilization of nurse-led models of care, patient outcomes, and patient and provider experiences.

Results: To date, findings from this study show that across three diferent nurse-led care models in Colorado, patients who were Hispanic and those living in rural areas were more likely to use phone rather than video telehealth visits.^1^ Additional results from patient surveys showed that those who had video telehealth visits had higher trust in the service provided than those who had phone visits. Provider surveys across the State showed consistent positive responses to the ease of use of telehealth with their patients.^1^

Additional study findings are expected. Publications can be found here (https://reporter.nih.gov/project-details/10321967).

#### Primary Care Relevance

Findings from this study help inform how well telehealth approaches impact primary care access and utilization for the most vulnerable patients.

#### AHRQ Primary Care Priority Area

Research to improve primary care, including regarding quality, access and afordability, the workforce, care delivery models, financing, digital healthcare, person-centeredness, and health equity.

1 Barton AJ, Amura CR, Willems EL, Medina R, Centi S, Hernandez T, Reed SM, Cook PF. Patient and Provider Perceptions of COVID-19-Driven Telehealth Use From Nurse-Led Care Models in Rural, Frontier, and Urban Colorado Communities. J Patient Exp. 2023 Jan 25;10:23743735231151546. doi: 10.1177/23743735231151546. PMID: 36741820; PMCID: PMC9893383.36741820

## Emerging Research Spotlights

This section includes descriptions of selected studies that do not yet have publications or findings.

### S1 Developing a Dashboard to Help Clinical Teams Prioritize and Manage Vulnerable Patients with Multiple Chronic Conditions

This study will use advanced analytics to identify patients with multiple chronic conditions and socially determined barriers to care, and then develop and test an EHR-based dashboard to help clinical teams ensure these patients receive high-quality primary care.

Portrait of Richard W. Grant, MD, MPH

PI Name: Richard W. Grant, MD, MPH

Grant Title: Care System Analytics to Support Primary Care Patients with Complex Medical and Social Needs (https://reporter.nih.gov/project-details/10259671)

Institution: Kaiser Foundation Research Institute

Grant Type: R18 (Research Demonstration and Dissemination Project)

Grant Period: 09/30/2019 – 09/29/2023

Topic Areas: Digital Healthcare; Public Health and Community Integration; Practice and Quality Improvement; Multiple Chronic Conditions

#### What is the research about?

People living with multiple chronic conditions (MCC) ofen experience barriers to receiving the high-quality, evidence-based primary care they need due to the various social, behavioral, and economic factors they face. For this project, the research team is using advanced analytics to identify which patients with MCC are at highest risk for facing socially determined barriers to care. The team is then developing an electronic health record (EHR) based dashboard that can be used by clinical teams to prioritize their most vulnerable MCC patients and help manage their care. The research team will evaluate the use of this dashboard in three Kaiser Permanente organizations providing care in lower income communities: Richmond, CA; Rainier Valley, WA; and Aurora, CO. The team will use transparent analytics and design the dashboard in such a way that it can be adapted and used in diferent clinical settings.

Results from this study are forthcoming. Current and future publications from this grant will be posted here (https://reporter.nih.gov/project-details/10259671).

#### Primary Care Relevance

The dashboard created through this grant will be able to be adapted by various primary care health systems to reduce barriers to care for patients who are both socially and medically complex.

#### AHRQ Primary Care Priority Area

Research on management of clinical areas unique to primary care, such as multiple chronic conditions, preventive care, undiferentiated syndromes, or behavioral and mental healthcare that is integrated within primary care.

### S2 Using EHR-Based Simulations to Reduce Diagnostic Errors in Ambulatory Care Settings

This project will develop a library of EHR-based simulations that can be used to train clinicians to change their EHR use patterns and improve diagnostic safety in ambulatory care settings.

Portrait of Jefrey Gold, MD

PI Name: Jefrey Gold, MD

CoPI Name: Raj Ratwani, PhD, MPH

Grant Title: A Turn-Key EHR Simulation Program to Reduce Diagnostic Error in Ambulatory Care (https://reporter.nih.gov/project-details/10470775)

Organization: Oregon Health & Science University

Grant Type: R18 (Research Demonstration and Dissemination Projects)

Grant Period: 09/30/2019 – 08/31/2024

Topic Areas: Digital Healthcare; Practice and Quality Improvement

#### What is the research about?

Diagnostic errors are ofen caused by clinicians not being able to access or synthesize the complex medical information they need for medical decision making. Making diagnoses in an ambulatory care setting requires processing information collected over a long period of time, across multiple individual encounters, and across transitions of care. Use of electronic health records (EHRs) can contribute to diagnostic errors, ofen because of system design issues and poor user training for clinicians. Simulation is a powerful tool that can be used to both systematically study the ways EHRs contribute to diagnostic errors, and train clinicians to prevent them.

For this grant, the research team will use a combination of administrative and claims data to identify diagnoses at risk for diagnostic error in ambulatory care settings and the EHR use errors associated with those errors. The researchers will use this data to develop simulations for five ambulatory care settings and validate the use of the simulation activities as a training tool to change clinician EHR use patterns and reduce diagnostic errors. The simulations library the research team develops (including simulation materials, scripts, and EHR charts) will be shared via an online repository along with applications that will allow the simulations to be loaded into all major EHR systems for broad dissemination and implementation.

Results from this study are forthcoming. Current and future publications from this grant will be posted here (https://reporter.nih.gov/project-details/10470775).

#### Primary Care Relevance

The library of validated EHR-based simulation exercises that this project plans to develop has the potential to train clinicians in ambulatory care settings to change their EHR use patterns and reduce diagnostic errors.

#### AHRQ Primary Care Priority Area

Harnessing data and technology to conduct research on characteristics of primary care that may influence patient outcomes, such as whole person care, care coordination, continuity of care, and comprehensiveness of care.

### S3 Implementing and Evaluating the Use of a Mobile Health Tool to Help Address Medication Non-Adherence

This study is implementing and evaluating the use of a mobile health tool for collecting patient-reported outcomes (PROs) in community pharmacies to address medication non-adherence.

Portrait of Margie Snyder, PharmD, MPH

PI Name: Margie Snyder, PharmD, MPH

Grant Title: An Evaluation of the Spread and Scale of PatientToc from Primary Care to Community Pharmacy Practice for the Collection of Patient-Reported Outcomes (https://reporter.nih.gov/project-details/10107723)

Institution: Purdue University

Grant Type: R18 (Research Demonstration and Dissemination Projects)

Grant Period: 04/01/2019 – 03/31/2024

Topic Areas: Digital Healthcare; Person-centered care

#### What is the research about?

Dispensed prescription histories and claims data typically are used to identify medication non-adherence in ambulatory care settings. However, collecting PROs via mobile health applications ofers new opportunities for understanding and addressing medication issues and non-adherence.

This study adapted and is testing PatientToc™, a previously developed mobile health sofware for collecting PROs in primary care, for use in community pharmacies to address medication non-adherence. First, the study team partnered with pharmacies in Indiana, Minnesota, and Wisconsin to conduct a pre-implementation developmental formative evaluation to understand existing workflows and practices for identifying medication non-adherence in community pharmacies, and to identify potential barriers and facilitators to implementing PatientToc™. Based on the information collected, the team created an implementation toolkit. Next, the study team worked with one pharmacy in each state to implement PatientToc™ and conduct a plan-do-study-act cycle to refine the toolkit and implementation facilitation plans. The team then spread implementation of PatientToc™, using the updated toolkit, to 3-5 locations per state. Finally, the team will conduct a rigorous evaluation using interviews, observational data, and administrative data to understand the impact of implementing PatientToc™ in community pharmacies on the quality of care and patient health outcomes.

Results from this study are forthcoming. Current and future publications from this grant will be posted here (https://reporter.nih.gov/project-details/10107723).

#### Primary Care Relevance

Community pharmacies may be in a better position than primary care clinicians for resolving medication issues and non-adherence, allowing patients to benefit from prescribed medications as intended by their primary care providers.

#### AHRQ Primary Care Priority Area

Harnessing data and technology to conduct research on characteristics of primary care that may influence patient outcomes, such as whole person care, care coordination, continuity of care, and comprehensiveness of care.

### S4 Does Support for CDS Implementation Increase the Use of Patient-Centered Care to Treat Chronic Pain in Primary Care?

This grant develops and tests a clinical decision support (CDS) tool to help primary care clinicians work with their patients to choose a pain treatment approach that best balances the potential risks and benefits for the individual patient.

Portrait of Christopher A. Harle; PhD

PI Name: Christopher A. Harle; PhD

CoPI Name: Ramzi G. Salloum, PhD

Grant Title: Scaling Interoperable Clinical Decision Support for Patient-Centered Chronic Pain Care (https://reporter.nih.gov/project-details/10488223)

Organization: University of Florida

Organization Type: School of Medicine

Grant Type: R18 (Research Demonstration and Dissemination Projects)

Grant Period: 09/13/2021 – 8/31/2024

Topic Areas: Person-Centered Care, Practice and Quality Improvement, Digital Healthcare

#### What is the research about?

The research team is providing tailored implementation support for primary care clinics to use an existing interoperable CDS tool (Pain Manager) for shared decision making to treat chronic pain. The researchers are then examining if the tailored implementation support increases the adoption of the CDS tool and use of shared decision making (SDM). In addition, the research team is collecting data and feasibility information to prepare for a multi-site pragmatic trial to test the efectiveness of Pain Manager, with implementation support, to increase SDM and improve patient-reported pain and physical function outcomes.

[underlined: CDS] describes a range of tools that are used to help support decision-making in the clinical workflow. These tools are ofen integrated into the electronic health record, and can include alerts or reminders for clinicians, clinical guideline information, condition-specific order sets, diagnostic support, or other tools.

[underlined: SDM] is a collaborative process in which patients and clinicians work together to make healthcare decisions informed by evidence; the care team’s knowledge and experience; and the patient’s values, goals, preferences, and circumstances.

Results from this study are forthcoming. Current and future publications from this grant will be posted here (https://reporter.nih.gov/project-details/10488223).

#### Primary Care Relevance

This study has the potential to develop and disseminate clinical decision support technology that can be used in primary care to help clinicians work with patients to choose safe and patient-centered care options to treat chronic pain.

#### AHRQ Primary Care Priority Area

Harnessing data and technology to conduct research on characteristics of primary care that may influence patient outcomes, such as whole person care, care coordination, continuity of care, and comprehensiveness of care.

### S5 Developing a Mobile Tool to Improve Self-Care and Shared Decision-Making for Patients with Chronic Conditions

This study develops and tests a strategy for collecting patient-reported outcomes from people living with chronic disease, and then integrating the data into primary care workflows to support self-care and shared decision making.

Portrait of Jane Jih, MD, MPH, MAS

PI Name: Jane Jih, MD, MPH, MAS

Grant Title: Mobile Patient-Reported Outcomes for Value and Efectiveness (mPROVE) (https://reporter.nih.gov/project-details/10246841)

Organization: University of California, San Francisco

Organization Type; Department: School of Medicine; Internal Medicine

Grant Type: U18 (Research Demonstration / Cooperative Agreement)

Grant Period: 09/01/2019 – 08/31/2024

Topic Areas: Person-Centered Care; Digital Healthcare, Practice and Quality Improvement

#### What is the research about?

The collection and sharing of patient-reported outcomes (PROs) – such as symptoms of depression, anxiety, mood, sleep, and cognitive function – can give people living with chronic conditions helpful information for understanding and managing their own health. In addition, clinical teams can use PROs to support shared decision-making with patients as they jointly develop and revise care plans. The widespread availability of mobile phones allows researchers to collect PRO data when and where people experience symptoms.

In this study, the research team will develop a smart phone app for patients to share PROs in English and Chinese. Using the app, patients living with one or more chronic disease will report on their physical and mental health-related quality of life (using the PROMIS-29 (https://www.healthmeasures.net/explore-measurement-systems/promis)). The research team will integrate patients’ responses into the University of California, San Francisco’s electronic health record (EHR). To support use of the PROs within the primary care workflow, the team will use SMART-on-FHIR technology to highlight the patient’s PRO results within the EHR encounter without requiring an additional login or search by the clinician. The research team will conduct participatory design sessions, field testing, workflow prototyping, and pilot testing of the app with patients, clinicians, and clinic staf.

The research team will also conduct a single-arm prospective interventional feasibility and acceptability study with 30 patients to evaluate implementation and the efectiveness of the app on improving patient outcomes.

Results from this study are forthcoming. Publications will be posted here (https://reporter.nih.gov/project-details/10246841).

#### Primary Care Relevance

This study will develop and test a strategy for collecting PROs from a diverse population of patients with chronic disease, and then seamlessly integrate the data into primary care workflows to support self-care and shared decision making.

#### AHRQ Primary Care Priority Area

Research to improve primary care, including regarding quality, access and afordability, the workforce, care delivery models, financing, digital healthcare, person-centeredness, and health equity.

### S6 Can an Electronic Shared Decision-Making Tool Increase the Uptake of Collaborative Care for Racial and Ethnic Minority Patients with Depression?

This study examines an approach for improving clinician and patient participation in collaborative care to treat depression among people from racial and ethnic minority groups.

Portrait of Nathalie Moise; MD, MS

PI Name: Nathalie Moise; MD, MS

Grant Title: TRANSFORM DEPCARE: A Theoretical Approach to Improving Patient Engagement and Shared Decision Making for Minorities in Collaborative Depression Care (https://reporter.nih.gov/search/ObfktFBT3UyfZcZ6_XyB_w/project-details/10214675)

Organization: Columbia University Health Sciences

Organization Type; Department: School of Medicine; Internal Medicine

Grant Type: RO1 (Research Project)

Grant Period: 09/30/2017 – 7/31/2023

Topic Areas: Behavioral Health and Substance Use Disorders, Person-Centered Care, Digital Healthcare

#### What is the research about?

Using implementation science and user centered design methods, the research team will design a multi-level intervention for sustaining collaborative care models. This will include developing and refining an interactive SDM tool to help patients and clinicians decide together if collaborative care for depression is the right treatment approach for the patient. Using a provider level cluster randomized control trial in 5 primary care clinics, the research team will assess the efectiveness of the strategy (technical assistance for care managers, provider education, and an automated SDM process for patients) on provider behavior and patient enrollment in collaborative care, as well as patient adherence to depression treatment and impact on depressive symptoms.

[underlined: Collaborative care] for depression in primary care incorporates depression care managers who provide antidepressant adherence counseling and/or psychotherapy for patients. Collaborative care has been found to greatly improve depression remission, particularly for people from racial and ethnic minority groups, as well as reduce mortality and healthcare costs. However, clinician referral rates to collaborative care and patient engagement rates remain low.

[underlined: SDM] is a collaborative process in which patients and clinicians work together to make healthcare decisions informed by evidence, the care team’s knowledge and experience, and the patient’s values, goals, preferences, and circumstances. Family members and caregivers also play an important role in SDM.

Results from this study are forthcoming. Current and future publications from this grant will be posted here (https://reporter.nih.gov/search/ObfktFBT3UyfZcZ6_XyB_w/project-details/10214675).

#### Primary Care Relevance

This study has the potential to produce a scalable electronic SDM (eSDM) tool to efectively improve the sustainability of collaborative care programs.

#### AHRQ Primary Care Priority Area

Harnessing data and technology to conduct research on characteristics of primary care that may influence patient outcomes, such as whole person care, care coordination, continuity of care, and comprehensiveness of care.

### S7 Identifying How to Improve Health Outcomes for Children in Foster Care

This study evaluates the impact of diferent healthcare delivery models on health outcomes for children in foster care and examines the factors that contribute to variations in healthcare use and health outcomes for these youth.

Portrait of Sarah J. Beal, PhD

PI Name: Sarah J. Beal, PhD

Grant Title: Examining the Impact of Healthcare Systems Changes on Healthcare Use and Health Outcomes for Children in Foster Care (https://reporter.nih.gov/search/n66NDW8nr0i-RMPuB6Y4sw/project-details/10513989)

Institution: Cincinnati Childrens Hospital Medical Center

Grant Type: R01 (Research Project)

Grant Period: 09/30/2022–07/31/2027

Topic Areas: Health Equity, Healthcare Systems and Infrastructure

#### What is the research about?

Children in foster care experience worse physical and behavioral health outcomes than other children. The health risks for children in foster care are further compounded due to the frequent communication failures between the healthcare and child welfare systems.

This study uses linked child welfare and electronic health record data from the past 12 years for over 9,000 patients, as well as Medicaid claims data and child and caregiver health status reports for a subset of 200 patients. This data will be used to compare healthcare use and outcomes for patients engaged in diferent models of care: mandated healthcare visits at the time of foster care placement alone; mandated visits, primary care, and specialty care all delivered in the same healthcare system; and coordinated information sharing between the healthcare system and the child welfare system. The research team also seeks to identify how child welfare system factors (e.g., foster care placement), caregiver characteristics (e.g., perceptions of healthcare), and child characteristics (e.g., diagnoses, age, and race) impact a child’s healthcare use and health outcomes over time.

Results from this study are forthcoming. Current and future publications from this grant will be posted here (https://reporter.nih.gov/search/n66NDW8nr0i-RMPuB6Y4sw/project-details/10513989).

#### Primary Care Relevance

This study will help identify which healthcare delivery models work best to care for children in foster care, and which factors are the greatest drivers of healthcare use and outcomes for these children. These findings can be used to implement health delivery practice changes, ofen in primary care, to improve the health outcomes of these vulnerable youth.

#### AHRQ Primary Care Priority Area

Research to improve primary care, including regarding quality, access and afordability, the workforce, care delivery models, financing, digital healthcare, person-centeredness, and health equity.

### S8 Understanding How Nurse Practitioners Increase Access to Primary Care

This study looks at how much adding nurse practitioners to primary care teams increases access to care, particularly for patient populations that have traditionally faced barriers to access.

Portrait of Hannah Neprash, PhD

PI Name: Hannah Neprash, PhD

Grant Title: The Role of Nurse Practitioners in Improving Access to Primary Care (https://reporter.nih.gov/project-details/10450283)

Institution: University of Minnesota

Organization Type: School of Public Health

Grant Type: R03 (Small Research Grants)

Grant Period: 04/01/2022 – 03/31/2024

Topic Areas: Primary Care Workforce, Health Equity

#### What is the research about?

The increasing prevalence of nurse practitioners (NPs) on primary care teams has the potential to improve access to care. This study will examine changes in access to care for new patients afer a NP joins a primary care practice.

The research team will use a database of all-payer claims and electronic health record data from a nationwide sample of primary care clinicians to analyze access to care. This dataset allows the research team to see who provided the health care services in addition to who billed for the care; construct measures of access based on scheduling data; and compare patient care across all payers (including Medicaid patients and commercially insured patients).

To measure access, the research team will look at changes in the share of visits provided to new patients, with a focus on uninsured patients; patients on Medicaid; and patients who self-identify as Black, Indigenous, or as a person of color. The team will also examine changes to wait times for appointments, the share of visits provided on evenings and weekends, and the share of walk-in visits.

Results from this study are forthcoming. Publications from this grant will be posted here (https://reporter.nih.gov/project-details/10450283).

#### Primary Care Relevance

This study will help the field of primary care quantify how much adding an NP to a primary care team helps to improve access to care and reduce access disparities.

#### AHRQ Primary Care Priority Area

Research to improve primary care, including regarding quality, access and afordability, the workforce, care delivery models, financing, digital healthcare, person-centeredness, and health equity.

### S9 Using Integrated Social and Medical Risk Data Dashboards to Improve Chronic Disease Management and Prevention

This project will enhance and evaluate the impacts of dashboards sharing integrated social and medical risk data to improve coordination between clinical and community settings.

Group photo of Danielle Hessler-Jones (PI); Caroline Fichtenberg, Karis Grounds, Nicole Blumenfeld, Laura Gottlieb, Yuri Cartier, Matt Pantell

Project Team: Danielle Hessler-Jones (PI); Caroline Fichtenberg, Karis Grounds, Nicole Blumenfeld, Laura Gottlieb, Yuri Cartier, Matt Pantell

Grant Title: Using social and medical data integration to improve primary care and population level chronic disease prevention and management (https://reporter.nih.gov/project-details/10259697)

Organizations: University of California, San Francisco; 2-1-1 San Diego

Grant Type: R18 (Research Demonstration and Dissemination Project)

Grant Period: 09/30/2019 – 09/29/2023

Topic Areas: Public Health and Community Integration, Digital Healthcare, Person-Centered Care

#### What is the research about?

San Diego’s Community Information Exchange (CIE) is a data-sharing system that allows health clinics and social service organizations to share information about patients’ social risk factors and use of social services with the goal of improving care coordination for vulnerable patients. The CIE allows primary care clinicians to refer patients to needed social services (such as food banks, housing support services, benefits assistance, or medical-legal partnerships) and take relevant social risk factor information into consideration at the point of care when developing treatment plans.

A Centers for Disease Control and Prevention (CDC) grant is supporting the integration of the CIE platform into the electronic health systems of three federally qualified health centers (FQHCs) to facilitate referrals between the clinics and social service agencies. This AHRQ grant builds on that efort by enhancing the CIE tool and evaluating its impact on efectiveness of the CIE for cross sector care coordination in both clinical and community settings. The research team is first identifying key barriers and facilitators among stakeholders to using social risk data, and then using that information to refine the CIE dashboards. The research team is then conducting a mixed-method evaluation to examine the adoption and impacts of these improved CIE dashboards.

Results from this study are forthcoming. Future publications from this grant will be posted here (https://reporter.nih.gov/project-details/10259697).

#### Primary Care Relevance

The CIE is a national model for innovative multi-sector care coordination. Findings from this evaluation will help inform similar eforts across the country to integrate social and medical services in primary care to improve health outcomes for vulnerable patients.

#### AHRQ Primary Care Priority Area

Harnessing data and technology to conduct research on characteristics of primary care that may influence patient outcomes, such as whole person care, care coordination, continuity of care, and comprehensiveness of care.

### S10 Enhancing a Mobile Health App for Patient Asthma Symptom Monitoring During the COVID-19 Pandemic

This supplemental project to an existing grant enhances a mobile health intervention for home monitoring of asthma symptoms with COVID-19 symptom screening.

Portrait of Robert S. Rudin, PhD

PI Name: Robert S. Rudin, PhD

Grant Title: Integrating Patient-Reported Outcomes into Routine Primary Care: Monitoring Asthma Between Visits (https://reporter.nih.gov/project-details/10175400)

Organization: RAND Corporation

Organization Type: Research Institute

Grant Type: R18 (Research Demonstration and Dissemination Project)

Grant Period: 09/30/2018 – 04/30/2023

Topic Areas: COVID-19, Digital Healthcare; Practice and Quality Improvement

#### What is the research about?

People living with asthma faced new and daunting risks during the COVID-19 pandemic. First, the potential respiratory complications of a COVID-19 infection can be especially dangerous for people living with asthma. In addition, getting routine care and filling prescriptions to manage a chronic condition became more dificult during the pandemic.

In their primary AHRQ grant (https://reporter.nih.gov/project-details/9984366), this research team is scaling a mobile health (mHealth) intervention to collect and monitor asthma symptoms between primary care visits. This intervention includes the use of a mHealth app through which patients regularly report their asthma symptoms. The intervention also includes a corresponding model to help clinics routinely monitor the patient-reported outcomes collected via the app.

For this COVID supplemental grant, the research team is enhancing the mHealth app to include screening for COVID-19 symptoms and to disseminate COVID-19 related health information to patients. In addition, the team worked to identify how to most efectively recruit patients to participate in the mHealth intervention during the pandemic. Finally, the team is using electronic health record data to identify which patients are most likely to benefit from home monitoring of asthma symptoms.

Results from this study are forthcoming. Current and future publications from this grant will be posted here (https://reporter.nih.gov/project-details/10175400).

#### Primary Care Relevance

This study will help build an understanding about how to use mobile health technology to keep patients with chronic conditions safe and minimize strain on critical care capacity during future COVID-19 surges or similar events.

#### AHRQ Primary Care Priority Area

Research to improve primary care, including regarding quality, access and afordability, the workforce, care delivery models, financing, digital healthcare, person-centeredness, and health equity.