# AHRQ Digital Healthcare Research Program

At a Glance 2021

## Our Purpose

The AHRQ Digital Healthcare Research Program (DHR) funds research that informs and drives the transformation of digital healthcare. Our studies deliver actionable findings to define how technologies work best for patients, clinicians, and health systems. Our goal, always, is to improve healthcare quality and safety.

## Our Focus

In 2021, AHRQ-funded studies focused on technologies that engage and empower patients, and optimize and advance care delivery—with an emphasis on using patient-reported data to support patient-centeredness and improve care decisions.

## Our Impact

AHRQ has invested $158 million among the projects that were active during 2021, comprising funding that spans FY2015 to 2026 for research of varying timeframes. Those 113 ongoing projects have resulted in significant impacts and progress on behalf of the American public. In 2021, AHRQ committed $30 million of that total, including:

- $14.4 million in funding from DHR appropriation.
- $11 million in funding from the Patient-Centered Outcomes Research Trust Fund.
- $4.6 million in funding from General Health Services Research appropriation.

The Improving Healthcare Through AHRQ’s Digital Healthcare Research Program 2021 Year in Review (https://digital.ahrq.gov/program-overview/research-reports/2021-year-review) highlights 18 research stories. Completed research stories amplify and demonstrate the impact of AHRQ investments. Emerging research stories highlight new and innovative projects that address important AHRQ priority areas, such as advancing health equity or improving care during patient transitions.

## Key Research Themes

### Engaging and Empowering Patients

Story Title | Impact Statement | Principal Investigator(s) | Research Type
The Clinical Decision Support Innovation Collaborative: Including the Patient’s Voice in Care (https://digital.ahrq.gov/program-overview/research-stories/clinical-decision-support-innovation-collaborative-including-patients-voice-care); Research Investment: $14,478,819 | The Clinical Decision Support Innovation Collaborative will integrate perspectives from diverse stakeholders to produce resources and evidence to make clinical decision support more valuable and meaningful to patients, clinicians, and healthcare systems. | Prashila Dullabh, National Opinion Research Center at the University of Chicago | Emerging
Identifying Patients With High Need During Care Transitions to Improve Care and Meet Social Needs (https://digital.ahrq.gov/program-overview/research-stories/identifying-patients-high-need-during-care-transitions-improve-care-and-meet-social-needs); Research Investment: $1,950,923 | Using health information exchange to identify high-need patients during care transitions can facilitate cross-sector communication, improve care continuity, and reduce rehospitalizations and other acute care. | Sharon Hewner, State University of New York at Buffalo | Emerging
Breathing Easy: Virtual Medication Education for Patients With Chronic Obstructive Pulmonary Disease (https://digital.ahrq.gov/program-overview/research-stories/breathing-easy-virtual-medication-education-patients-chronic-obstructive-pulmonary-disease); Research Investment: $1,999,997 | Virtual visits with members of a pharmacy team can support patients recently discharged from the hospital with their medication use and improve outcomes among chronic obstructive pulmonary disease patients at high risk for readmission. | Valerie Press, Joanna Abraham, and Vineet Arora, University of Chicago | Emerging
Opening a Window to Depression (https://digital.ahrq.gov/program-overview/research-stories/opening-window-depression); Research Investment: $1,170,087 | Many people with depression who do not have upcoming medical appointments go undiagnosed. An online questionnaire can help get them into treatment. | Neda Laiteerapong, University of Chicago | Completed
Hanging Out With CoolCraig: Self-Regulation for Youth With Attention Deficit Hyperactivity Disorder (https://digital.ahrq.gov/program-overview/research-stories/hanging-out-coolcraig-self-regulation-youth-attention-deficit); Research Investment: $378,705 | A wearable digital healthcare intervention to promote self-regulation among children with attention deficit hyperactivity disorder and their parents is a promising method to support adherence to treatment. | Kimberley Lakes, University of California Riverside | Completed

### Optimizing Care Delivery for Clinicians

Story Title | Impact Statement | Principal Investigator(s) | Research Type
Patient-Facing Clinical Decision Support to Improve Blood Pressure (https://digital.ahrq.gov/program-overview/research-stories/patient-facing-clinical-decision-support-improve-blood-pressure); Research Investment: $938,621 | Translating hypertension guidelines into a patient-facing clinical decision support tool can engage patients in blood pressure management. | David Dorr, Oregon Health and Science University | Completed
Sharing the Decision, Sharing the Data: Interoperable Clinical Decision Support Tool for Chronic Pain Management (https://digital.ahrq.gov/program-overview/research-stories/sharing-decision-sharing-data-interoperable-clinical-decision-support-tool-chronic-pain-management); Research Investment: $2,952,700 | The tailored and scaled implementation and evaluation of AHRQ’s interoperable clinical decision support tools, MyPAIN and PainManager, have the potential to expand upon the shared decision-making processes used in chronic pain management to improve patient care and obtain optimal patient outcomes. | Christopher Harle and Ramzi Salloum, University of Florida | Emerging
Improving Electronic Health Record Usability for Patient Safety (https://digital.ahrq.gov/program-overview/research-stories/improving-electronic-health-record-usability-patient-safety); Research Investment: $1,224,973 | Analysis of patient safety event reports showed an association between electronic health record (EHR) usability and patient safety in both adults and children and led to development of an EHR assessment tool that healthcare facilities can use to identify usability and safety issues. | Raj Ratwani, MedStar Health Research Institute | Completed
Choosing What Clinicians See in an Electronic Health Record Can Reduce Cognitive Burden and Improve Decision Making (https://digital.ahrq.gov/program-overview/research-stories/choosing-what-clinicians-see-electronic-health-record-can-reduce-cognitive-burden-and-improve); Research Investment: $965,791 | Giving clinicians the ability to customize the patient electronic health record display reduces cognitive burden, saves time, and supports decision making in busy clinical environments. | Yalini Senathirajah, University of Pittsburgh | Completed
Designing Digital Healthcare Technology to Support Cognitive Team Work in Pediatric Trauma Settings (https://digital.ahrq.gov/program-overview/research-stories/designing-digital-healthcare-technology-support-cognitive-team); Research Investment: $2,493,921 | Simple and informative graphic displays in emergency department trauma bays can streamline and expedite information sharing across caregiver roles to improve patient care and safety. | Ayse Gurses, Johns Hopkins University | Completed
Understanding Hospitals’ Resilience and Reponse to the COVID-19 Pandemic (https://digital.ahrq.gov/program-overview/research-stories/understanding-hospitals-resilience-and-reponse-covid-19-pandemic); Research Investment: $894,961 | Pandemics put extraordinary demands on healthcare capacity and studying hospital resilience can increase our preparedness for future pandemics. | David Kaufman and Yalini Senathirajah, SUNY Downstate Medical Center | Emerging
Visual Learning: Displaying the Data for Hypertension Management (https://digital.ahrq.gov/program-overview/research-stories/visual-learning-displaying-data-hypertension-management); Research Investment: $2,230,821 | A clinical decision support tool helps patients and physicians use at-home measured blood pressure data to better understand hypertension control and inform shared treatment decisions. | Richelle Koopman, University of Missouri at Columbia | Completed
Digital Tools to Support Care Coordination for People With Depression (https://digital.ahrq.gov/program-overview/research-stories/digital-tools-support-care-coordination-people-depression); Research Investment: $1,852,918 | Adaptation of a digital mental health intervention has the potential to improve the coordination of and access to mental health services in ambulatory care settings. | Emily Lattie, Northwestern University | Emerging
Predictive Modeling to Improve Screening and Referral for Unmet Need (https://digital.ahrq.gov/program-overview/research-stories/predictive-modeling-improve-screening-and-referral-unmet-need); Research Investment: $1,967,217 | Using predictive modeling and clinical decision support tools to identify people with unmet social needs has the potential to increase referrals to social services. | Joshua Vest, Indiana University-Purdue University at Indianapolis | Emerging

### Supporting Health Systems in Advancing Care Delivery

Story Title | Impact Statement | Principal Investigator(s) | Type
Virtual Pharmacy Improves Medication Use and Patient Safety in Palliative Care (https://digital.ahrq.gov/program-overview/research-stories/virtual-pharmacy-improves-medication-use-and-patient-safety-palliative-care); Research Investment: $300,000 | Including virtual pharmacists in palliative care teams can reduce adverse drug interactions and increase the quality of life for people who are very ill. | Janet Bull, Four Seasons | Completed
The Telehealth Transition and Improving Health Systems (https://digital.ahrq.gov/program-overview/research-stories/telehealth-transition-and-improving-health-systems); Research Investment: $999,845 | Evaluation of the rapid transition to telehealth due to the COVID-19 pandemic will inform patient care post-COVID-19 to ensure equal access and high-quality care. | Kit Simpson and Jillian Harvey, Medical University of South Carolina | Emerging
Development of a Digital Healthcare Equity Framework (https://digital.ahrq.gov/program-overview/research-stories/development-digital-healthcare-equity-framework); Research Investment: $292,314 | A framework and guide to help creators and users of healthcare solutions that involve digital technologies ensure that their solutions are equitable. | Elham Hatef and Matthew Austin, Johns Hopkins University | Emerging
Guidelines for Meaningful and Effective Electronic Patient-Reported Outcomes Use in Clinical Settings (https://digital.ahrq.gov/program-overview/research-stories/guidelines-meaningful-and-effective-electronic-patient-reported); Research Investment: $2,445,560 | Governance, integration, and reporting are key systems-level principles that support incorporation of electronic patient-reported outcomes into clinical practice. | Danielle Lavallee, University of Washington | Completed