# V List of Projects Active in 2017

Table 11 Health Information Technology PA Grants

Exploratory and Developmental Grant to Improve Health Care Quality Through Health IT (R21)
Principal Investigator | Project Title | Funding Opportunity Announcement
Abraham, Joanna | An Etiology for Medication Ordering Errors in Computerized Provider Order Entry Systems | PA-14-001
Adelman, Jason Stuart | Assess Risk of Wrong Patient Errors in an Electronic Medical Record that Allows Multiple Records Open | PA-14-001
Asan, Onur | Perception and Use of a Patient Care Window to Improve Care and Family Engagement | PA-14-001
Avidan, Michael | Anesthesiology Control Tower: Feedback Alerts to Supplement Treatment (ACTFAST) | PA-14-001
Bardach, Naomi S. | Novel Information Technology to Create Patient-Integrated Quality Improvement | PA-14-001
Bauer, Nerissa San Luis | Improving Anxiety Detection in Pediatrics Using Health Information Technology | PA-14-001
Cartmell, Kathleen Buford | Reducing Hospital Readmission Rates by Implementing an Inpatient Tobacco Cessation Service Driven by Interactive-Voice Recognition Technology | PA-14-001
Choi, Sung | Personalized Engagement Tool for Pediatric Blood and Marrow Transplantation Patients and Caregivers | PA-14-001
Cohen, Lindsey | Relieving Anxiety in Children Undergoing Radiation Therapy through Virtual Preparation | PAR-HS-08-269
Cutrona, Sarah Leleiko | Open & Act: Tracking Healthcare Team Response to Electronic Health Record Asynchronous Alerts | PA-14-001
Dalal, Anuj K. | Interactive Patient-Centered Discharge Toolkit to Promote Self-Management During Transitions | PA-14-001
Dexheimer, Judith W. | Optimal Methods for Notifying Clinicians About Epilepsy Surgery Patients | PA-14-001
Dixon, Brian | Exploring the Utilization of and Outcomes from Health Information Exchange in Emergency Settings | PA-14-001
Dorsch, Michael | A Geofencing-Based Adaptive Messaging System to Support Patient Self-Management of a Low-Sodium Diet in Hypertension | PA-14-001
Dowding, Dawn | Development of Dashboards to Provide Feedback to Home Care Nurses | PA-14-001
Farris, Karen | Improving Adherence and Outcomes by Artificial Intelligence-Adapted Text Messages | PAR-HS-08-269
Federman, Alex D. | Development of an Electronic Medical Record-Integrated Enhanced After Visit Summary | PA-14-001
Ferucci, Elizabeth D. | Evaluation of the Impact of Telemedicine on Management of Rheumatoid Arthritis | PA-14-001
Gance-Cleveland, Bonnie | StartSmart^TM^: Health Information Technology to Improve Adherence to Prenatal Guidelines | PA-14-001
Goss, Foster R. | Natural Language Processing to Identify and Rank Clinically Relevant Information for EHRs in the Emergency Department | PA-14-001
Gray, Stacy W. | Empowering Cancer Patients Through Innovations in Information Technology-Based Reporting of Precision Medicine | PA-14-001
Hettinger, Aaron Zachary | Context is Critical: Understanding When and Why Electronic Health Record Related Safety Hazards Happen | PA-14-001
Holden, Richard | Power to the Patient: Design and Test of Closed-Loop Interactive Information Technology for Geriatric Heart Failure Self-Care | PA-14-001
Juckett, David | Phenotype Modeling and Outcome Mapping for Pain Management Decision Support | PAR-HS-08-269
Kazemi, Donna | mHealth Delivery of a Motivational Intervention to Address Heavy Drinking Among College Freshmen | PA-14-001
Kent, K Craig | Patient-Centered Postoperative Wound Surveillance Using Current Technology | PAR-HS-08-269
Kutney-Lee, Ann | Electronic Health Record Use, Work Environments, and Patient Outcomes | PA-14-001
Lacson, Ronilda | Automated Notification for Follow-Up Testing Recommendations Across Care Settings | PAR-HS-08-269
Lee, Joyce | Patient-Centered Data Visualizations for Diabetes | PA-14-001
Leroy, Gondy | Enabling Large-Scale Research on Autism Spectrum Disorders Through Automated Processing of Electronic Health Record Using Natural Language Understanding | PA-14-001
Leung, May May | Intervention INC: Interactive Nutrition Comics for Urban Minority Youth | PA-14-001
Levin, Scott Ryan | HopScore: An Electronic Outcomes-Based Emergency Triage System | PA-14-001
Lindquist, Lee A. | Improving Outpatient Safety of Older Adults through Electronic Patient Portals | PA-14-001
Liss, David T. | Using Location-Based Smartphone Alerts Within a System of Care Coordination | PA-14-001
Malone, Daniel C. | Individualized Drug Interaction Alerts | PA-14-001
Mazur, Lukasz | Enhancing Providers Ability to Follow-up on Abnormal Test Results | PA-14-001
McAlearney, Ann Scheck | Portals in Inpatient Care (PIC): Evaluating the Usability, Use and Patient Experience Associated with Patient Portal Technology at the Bedside | PA-14-001
Meguid, Robert A. | Surgical Risk Preoperative Assessment System (SURPAS) | PA-14-001
Mitchell, Suzanne | Treating Comorbid Depression During Care Transitions with Relational Agents | PA-14-001
Molfenter, Todd David | Payer Readiness for Technology Implementation (P-RTI) Tool Application and Assessment | PA-14-001
Moore, Susan Louise | Engaging Disadvantaged Patients in Sharing Patient-Generated Health Data and Patient-Reported Outcomes through Health Information Technology | PA-14-001
Morrow, Daniel | Collaborative Patient Portals: Computer-Based Agents and Patients | PAR-HS-08-269
Munson, Sean | Sharing Patient Lifelog Data with the Primary Care Team for Two Patient Populations: Preventative Care and Chronic Disease Management | PA-14-001
Nahm, Eun-Shim | A Theory-Based Patient Portal eLearning Program for Older Adults with Chronic Illnesses | PA-14-001
Ornstein, Steven | Learning From Primary Care EHR Exemplars About Health IT Safety | PA-14-001
Overby, Casey Lynnette | Electronic Health Record-linked Decision Support for Communicating Genomic Data | PAR-HS-08-269
Patel, Minal R. | Feasibility of a Clinician Training Program to Improve Patient-Provider Communication in the Presence of Health Information Technology Systems in the Exam Room | PA-14-001
Phillips, Robert | Trial of Aggregate Data Extraction for Maintenance of Certification and Raising Quality | PAR-HS-08-269
Pratap, Jayant | Using the Electronic Health Record to Identify Children Likely to Suffer Last-Minute Surgery Cancellation | PA-14-001
Primack, Brian A. | Sponsored Health Information Technology and Evidence-Based Prescribing among Medical Residents | PAR-HS-08-269
Rangachari, Pavani | Using Social Knowledge Networking (SKN) Technology to Enable Meaningful Use of EHR Technology | PA-14-001
Rao, Goutham | Improving Diagnosis of Hypertension in Children (IDHC) | PA-14-001
Schnipper, Jeffrey Lawrence | Electronic Medication Adherence Reporting and Feedback During Care Transitions | PA-14-001
Sherwin, Robert | Enhancing an Electronic Medical Record-Based Real-Time Sepsis Alert System Performance Through Machine Learning | PA-14-001
Singh, Hardeep | Improving Direct Notification of Abnormal Test Results via Patient Portals | PA-14-001
Snyder, Margie E. | Enhancing Clinical Decision Support Applications for Community Pharmacist-Delivered Medication Therapy Management | PA-14-001
Valdez, Rupa | Accessibility and Beyond: Designing Consumer Health Information Technology for Disabled Individuals | PA-14-001
Wernz, Christian | Evidence-based Contingency Planning for Electronic Health Record Downtime | PA-14-001
Xie, Anping | Development of a Clinical Decision Support Tool for Facilitating Naturalistic Decision-Making and Improving Blood Culture Utilization | PA-14-001
Ye, Lichuan | A Sleep Promotion Toolkit for Hospitalized Patients | PA-14-001
Yen, Po-Yin | Development and Evaluation of Sociotechnical Metrics to Inform Health IT Adaptation | PA-14-001
Disseminating and Implementing Evidence from Patient-Centered Outcomes Research in Clinical Practice Using Mobile Health Technology (R21)
Principal Investigator | Project Title | Funding Opportunity Announcement
Abujarad, Fuad | Patient Centered Virtual Multimedia Interactive Informed Consent (VIC) | RFA-HS-14-010
Bajaj, Jasmohan S. | Use of Patient Buddy Application to Disseminate Knowledge & Prevent Readmission | RFA-HS-14-010
Chrischilles, Elizabeth | Design and Testing of a Mobile Cardiovascular Risk Service with Patient Partners | RFA-HS-14-010
Connelly, Mark Andrew | Registry-Assisted Dissemination of Mobile Pain Management for Youth with Arthritis | RFA-HS-14-010
Oreskovic, Nicolas M | An Integrated Closed-Loop Feedback System for Pediatric Cardiometabolic Disease | RFA-HS-14-010
Rudin, Robert Samuel | Using mHealth and Patient-reported Outcomes to Deliver Evidence-Based Asthma Care | RFA-HS-14-010
Schnall, Rebecca | Use of mHealth Technology for Supporting Symptom Management in Underserved Persons Living with HIV | RFA-HS-14-010
Shah, Nirmish R. | Use of Mobile Technology to Improve Acute Care Utilization in Sickle Cell Disease | RFA-HS-14-010
Tulu, Bengisu | TJR Guru: A Mobile App for Shared Informed Decision Making in Total Joint Replacement Surgery | RFA-HS-14-010
Understanding Clinical Information Needs and Health Care Decision Making Processes in the Context of Health IT (R01)
Principal Investigator | Project Title | Funding Opportunity Announcement
Carayon, Pascale | Health Information Technology-Supported Process for Preventing and Managing Venous Thromboembolism | PA-11-198
Cohen, Deborah Jill | Clinical Information Needs of Community Health Centers for Health Information Technology (CLINCH-IT) | PA-11-198
Fairbanks, Rollin | Cognitive Engineering for Complex Decision Making and Problem Solving in Acute Care | PA-11-198
Flum, David R. | Developing Design Principles to Integrate Patient-Reported Outcomes (PROs) into Clinical Practice through Health Information Technology: Data, User Experience, and Workflow Requirements for PRO Dashboards | PA-11-198
Franklin, Amy | Opportunistic Decision Making Information Needs and Workflow in Emergency Care | PA-11-198
Gold, Jeffrey Allen | Electronic Health Record Solutions for Accurate Reporting of Data on Interprofessional Intensive Care Unit Rounds | PA-11-198
Gurses, Ayse Pinar | Care Transitions and Teamwork in Pediatric Trauma: Implications for Health Information Technology Design | PA-11-198
Harle, Christopher Albert | Designing User-Centered Decision Support Tools for Chronic Pain in Primary Care | PA-11-198
Koopman, Richelle J. | Optimizing Display of Blood Pressure Data to Support Clinical Decision Making | PA-11-198
Manojlovich, Milisa | The Effect of Health Information Technology on Healthcare Provider Communication | PA-11-198
Melton-Meaux, Genevieve | Discovery and Visualization of New Information from Clinical Reports in the Electronic Health Record | PA-11-198
Singh, Hardeep | Decision Making and Clinical Work of Test Result Follow-up in Health Information Technology Settings | PA-11-198
Wetterneck, Tosha Beth | Understanding Primary Care Teamwork in Context: Implications for Health Information Technology Design | PA-11-198
Windle, John | Optimizing the Electronic Health Record for Cardiac Care | PA-11-198
Understanding User Needs and Context to Inform Consumer Health IT Design (R01)
Principal Investigator | Project Title | Funding Opportunity Announcement
Bertoni, Alain | Maximizing the Impact of Electronic Personal Health Information Management (ePHIM) in Low-Income, Multiethnic Populations | PA-11-199
Jackson, Gretchen P. | Personal Health Information Needs and Practices for Maternal Fetal Care | PA-11-199
Matthews, Judith T. | Self-Management via Health Kiosk by Community-Residing Older Adults | PA-11-199
Ponto, Kevin | vizHOME: A Context-Based Health Information Needs Assessment Strategy | PA-11-199
Pratt, Wanda | Patients as Safeguards: Understanding the Information Needs of Hospitalized Patients | PA-11-199
Ralston, James | Patient Reminders and Notifications | PA-11-199
Ralston, James | Understanding and Honoring Patients with Multiple Chronic Conditions | PA-11-199
Safran, Charles | InfoSage: Information Sharing Across Generation and Environments | PA-11-199
Thompson, Haley S. | eHealth Activity among African American and White Cancer Survivors | PA-11-199
Turner, Anne M. | Addressing the Personal Health Information Management Needs of Older Adults | PA-11-199
Vawdrey, David Kent | Addressing Hospital Patient Information Needs Using a Personal Health Record Portal | PA-11-199
Zikmund-Fisher, Brian | Systematic Design of Meaningful Presentations of Medical Test Data for Patients | PA-11-199
Active Aging: Supporting Individuals and Enhancing Community-based Care Through Health IT (P50)
Principal Investigator | Project Title | Funding Opportunity Announcement
Gustafson, David H. | Bringing Communities and Technology Together for Healthy Aging | RFA-HS-10-016
Patient-Centered Outcomes Research Clinical Decision Support Leaning Network (U18)
Principal Investigator | Project Title | Funding Opportunity Announcement
Blumenfeld, Barry H. | Patient-Centered Outcomes Research Clinical Decision Support Learning Network | HS-15-003
Electronic Data Methods Forum: Second Phase (U18)
Principal Investigator | Project Title | Funding Opportunity Announcement
Edmunds, Margaret | AcademyHealth Electronic Data Methods Forum Second Phase | RFA-HS-13-004

Table 12 Other Health IT Funded Grants

AHRQ Conference Grant Program (R13)
Principal Investigator | Project Title | Funding Opportunity Announcement
Fridsma, Douglas Brian | AMIA Health Policy Conference | PA-13-017
Gill, Erica L. | e3iVR: Conference on Ethics in Investigational and Interventional Uses of Immersive Virtual Reality | PA-13-017
Career Development (K01, K08) Grants Focused on Health IT
Principal Investigator | Project Title | Funding Opportunity Announcement
Ancker, Jessica | Improving Healthcare Quality with User-Centric Patient Portals | PAR-09-087
Blecker, Saul B. | Health Information Technology in Heart Failure Care | PA-13-039
Gephart, Sheila Maria | Clinical Decision Support Optimizing Necrotizing Enterocolitis Prevention Implementation in Neonatal Intensive Care Unit | PA-13-039
Melnick, Edward | Clinical Decision Support for Mild Traumatic Brain Injury | PAR-09-085
Nanji, Karen C. | Preventing Perioperative Medication Errors and Adverse Drug Events Through the Use of Clinical Decision Support | PA-13-039
Smith, Angela B. | Developing an Interactive, Patient-Centered mHealth Tool to Enhance Post-Cystectomy Care | PA-13-039
Wasson, Lauren | Improving Diagnosis of Cardiovascular Disease in the Emergency Department Using Cognitive Informatics Tools | PA-13-039
Wen, Kuang-Yi | MyHealthPortal: Using an Electronic Portal to Empower Patients with Breast Cancer | PAR-09-087
Patient Centered Outcomes Research Pathway to Independence Award (K99/R00)
Principal Investigator | Project Title | Funding Opportunity Announcement
Lyles, Courtney | Engaging Diverse Patients in Using an Online Patient Portal | RFA-HS-13-002
Patient Centered Outcomes Research Mentored Clinical Investigator Award (K08)
Principal Investigator | Project Title | Funding Opportunity Announcement
Sharifi, Mahnoos H. | Using Electronic Health Records to Support Decision-Making in Pediatric Obesity Care | PA-13-180
Small Research Grant Program (R03)
Principal Investigator | Project Title | Funding Opportunity Announcement
Ellis, Charles | Speech Telerehabilition After Stroke: Proof-of-Concept and Feasibility | PA-15-147
Mendonca, Eneida | Virtualized Homes: Tools for Better Discharge Planning | PA-15-147
Saleem, Jason J. | Ambulatory Clinic Exam Room Design with Respect to Computing Devices to Enhance Patient Centeredness | PA-15-147
AHRQ Health Services Research Demonstration and Dissemination (R18)
Principal Investigator | Project Title | Funding Opportunity Announcement
Epstein, Jeff N. | Improving ADHD Behavioral Care Quality in Community-Based Pediatric Settings | PA-14-290
Jack, Brian | Implementation and Dissemination of ‘Gabby,’ a Health Information Technology System for Young Women, into Community-Based Clinical Sites | PA-14-290
Kroth, Philip | Minimizing Stress, Maximizing Success of Physician’s Use of Health Information | PA-13-046
McTigue, Kathleen M. | Maintaining Activity and Nutrition through Technology-Assisted Innovation in Primary Care | PA-09-071
Solberg, Leif | Optimizing the Value of Patient-Reported Outcome Measures in Improving Care Delivery through Health Information Technology | PA-14-290
AHRQ Health Services Research Projects (R01)
Principal Investigator | Project Title | Funding Opportunity Announcement
Adelman, Jason Stuart | Develop and Validate Health Information Technology Safety Measures to Capture Violations of the Five Rights of Medication Safety | PA-14-291
Adelman, Jason Stuart | Providing Evidence and Developing a Toolkit to Accelerate the Adoption of Patient Photographs in Electronic Health Records | PA-14-291
Aguilera, Adrian | Improving Diabetes and Depression Self-management Via Adaptive Mobile Messaging | PA-14-291
Alpern, Elizabeth | Improving the Quality of Pediatric Emergency Care Using an Electronic Medical Record Registry and Clinician Feedback | PA-09-070
Bates, David | Ensuring Safe Performance of Electronic Health Records | PA-13-045
Cummins, Mollie Rebecca | Electronic Exchange of Poisoning Information | PA-09-070
Dixon, Brian | Improving Population Health Through Enhanced Targeted Regional Decision Support | PA-09-070
Grannis, Shaun | Enhancing Patient Matching in Support of Operational Health Information Exchange | PA-14-291
Lambert, Bruce | Preventing Wrong-Drug and Wrong-Patient Errors with Indication Alerts in Computerized Provider Order Entry Systems | PA-14-291
Marcin, James | School-Based Tele-Physiatry Assistance for Rehabilitative and Therapeutic Services for Children with Special Health Care Needs Living in Rural and Underserved Communities | PA-14-291
McCarty, Carolyn A. | Improving Teen Care with Health Information Technology | PA-13-045
Patel, Vimla L. | Impact of Meaningful Use on Clinical Workflow in Emergency Departments | PA-13-045
Ratwani, Raj M. | Developing Evidence-based User Centered Design and Implementation Guidelines to Improve Health Information Technology Usability | PA-14-291
Schiff, Gordon David | Enhancing Medication Computerized Provider Order Entry Safety and Quality by Indications Based Prescribing | PA-13-045
Schnall, Rebecca | The Wise App Trial for Improving Health Outcomes in People Living With HIV (PLWH) | PA-14-291
Senathirajah, Yalini | Finding the Safer Way: Novel Interaction Design Approaches to Health Information Technology Safety | PA-14-291
Shapiro, Jason S. | Advancing Quality Measurement and Care Improvement with Health Information Exchange | PA-09-070
Siegel, Corey | Evaluating a Prediction Tool and Decision Aid for Patients with Crohn’s Disease | PA-09-070
Sockolow, Paulina | Information Needs of Homecare Nurses During Admission and Care Planning | PA-14-291
Stockwell, Melissa | PRISM: Personalized Reminders for Immunizations using Short Messaging Systems | PA-13-045
Stockwell, Melissa | SINC: Synchronized Immunization Notifications | PA-14-291
Vest, Joshua Ryan | Use of Push and Pull Health Information Exchange Technologies by Ambulatory Care Practices and the Impact on Potentially Avoidable Health Care Utilization | PA-14-291
Weiner, Saul | Integrating Contextual Factors into Clinical Decision Support to Reduce Contextual Error and Improve Outcomes in Ambulatory Care | PA-14-291
Xiong, Glen | Comparison of Asynchronous Telepsychiatry Alongside Synchronous Telepsychiatry in Skilled Nursing Facilities | PA-14-291
Yellowlees, Peter M. | A Clinical Trial to Validate an Automated Online Language Interpreting Tool with Hispanic Patients Who Have Limited English Proficiency | PA-14-291
Zhou, Li | Natural Language Processing to Improve Accuracy and Quality of Dictated Medical Documents | PA-14-291
Zhou, Li | Encoding and Processing Patient Allergy Information in Electronic Health Records | PA-13-045
Centers for Education and Research on Therapeutics (CERTs) (U19)
Principal Investigator | Project Title | Funding Opportunity Announcement
Lambert, Bruce | Tools for Optimizing Medication Safety (TOP-MEDS) | RFA-HS-11-004
Research Centers in Primary Care Practice-Based Research and Learning (P30)
Principal Investigator | Project Title | Funding Opportunity Announcement
Fiks, Alexander | National Center for Pediatric Practice Based Research and Learning | RFA-HS-12-002
Ornstein, Steven | Research Centers in Primary Care Practice Based Research and Learning | RFA-HS-12-002

Table 13 Health IT Contracts

Health IT Contracts
Organization | Project Title | Contract/IAA Number
The MITRE Corporation | Patient-Centered Outcomes Research Clinical Decision Support Prototype Development and Dissemination | 290-16-00001U