# IV Conclusion

Health IT research funded by AHRQ has played a critical role in identifying barriers and facilitators to successful adoption of new and existing healthcare technologies, improving implementation and use of health IT, and disseminating best practices and solutions for harnessing the potential of IT in the U.S. healthcare system. Many projects that were active during 2017 strengthened existing technologies or developed new technologies, assessed the feasibility of using health IT tools, and evaluated the impact of health IT on health services delivery or patient health outcomes. Furthermore, the Health IT Division’s funding focused on expanding health IT access to healthcare consumers through patient-facing technologies designed to expand access to health services and health information, improve quality and effectiveness of care, and facilitate PCOR using patient-generated health data. The work funded by AHRQ has made important advancements in developing and disseminating the evidence-base for health IT and shaping future priorities for the field of health IT.

Findings and lessons learned are shared through the AHRQ Health IT website (https://healthit.ahrq.gov/). Readers are invited to visit the website to learn more about all of the AHRQ resources, initiatives, and funded projects.