# II Health IT Division Projects

## A Funding Opportunities

The Health IT Division uses a variety of funding mechanisms to achieve its research goals, including grants and contracts. Each mechanism specifies the content, format, and timeline for deliverables, including periodic reporting requirements for completion of milestones and budget updates. Collectively, these mechanisms provide funding for a wide variety of health services research and administrative activities that are described in more detail below.

### Grants

Grants provide money, property, or other direct assistance for approved projects or activities to support a public purpose that does not directly benefit the government. Grant proposals are submitted to AHRQ in response to a funding opportunity announcement (FOA). One-time FOAs are known as a request for applications (RFAs), and recurring FOAs are known as program announcements (PAs).

There were 150 Health IT Division-funded grants active at any time during calendar year 2017, with lifetime AHRQ funding equaling $153.2 million. Lifetime AHRQ funding refers to the total financial support that AHRQ obligates to a project during the entire project period.

Grants active during calendar year 2017 were awarded under the following programs.

Health IT Funding Opportunities. Active grants were supported by the following ongoing or closed Health IT Division funding opportunities.

- Exploratory and Developmental Grant to Improve Healthcare Quality Through Health IT (R21) (PAR-08-269, PA-14-001): Provides funding for health IT exploratory and developmental research projects that support the conduct of short-term preparatory, pilot, or feasibility studies. There were 61 projects active during 2017 funded under these R21 program announcements.
- Disseminating and Implementing Evidence from Patient-Centered Outcomes Research in Clinical Practice Using Mobile Health Technology (R21) (HS-14-010): This FOA provides funding to develop and evaluate the effectiveness of novel approaches that use mobile health (mHealth) tools to enable the timely incorporation and appropriate use of PCOR evidence in clinical practice. Ten projects have been funded through this initiative and all were active in 2017.

Grant Highlight: HopScore: An Electronic Outcomes-Based Emergency Triage System (R21 HS024071) (https://healthit.ahrq.gov/ahrq-funded-projects/hopscore-electronic-outcomes-based-emergency-triage-system)

The “HopScore” tool aims to support objective triage decisions in the emergency department (ED) and improve patient differentiation based on outcomes data. HopScore uses easily obtained patient demographic and clinical information commonly collected at ED triage to predict patients’ risk for critical outcomes. The project, led by Dr. Scott Levin at Johns Hopkins University, is refining and piloting an outcomes-based ED triage tool to predict patients’ risk for time-sensitive critical health events.

Grant Highlight: Health Information Technology-Supported Process for Preventing and Managing Venous Thromboembolism (#R01 HS022086) (https://healthit.ahrq.gov/ahrq-funded-projects/health-information-technology-supported-process-preventing-and-managing-venous-thromboembolism)

Dr. Pascale Carayon and a team of investigators at the University of Wisconsin-Madison are developing health IT design requirements using a sociotechnical systems approach for preventing and managing venous thromboembolism (VTE). Using observations, interviews, focus groups, and a survey in four hospitals of an integrated healthcare system, researchers are identifying the cognitive and team work involved in VTE prevention and management that are informing the development of design requirements.

- Understanding Clinical Information Needs and Healthcare Decision Making Processes in the Context of Health IT (R01) (PA-11-198): Funds research aimed at elucidating the nature of cognition, task distribution, and work flow in healthcare delivery settings. While this program announcement is now closed, during 2017 there were 14 active projects funded through this program announcement.
- Understanding User Needs and Context to Inform Consumer Health IT Design (R01) (PA-11-199): Funds projects that help build a knowledge base about consumers’ personal health information management needs and practices and related design principles. This program announcement, now closed, funded 12 projects active in 2017.
- Active Aging: Supporting Individuals and Enhancing Community-Based Care Through Health IT (P50) RFA (HS-10-016): This FOA funded one research project with the objective of developing sustainable and reproducible strategies to translate research into practice effectively and efficiently. This RFA is now closed, and the project ended during 2017.
- Patient-Centered Outcomes Research Clinical Decision Support Learning Network (U18) RFA (HS-15-003): This funding supported the development of the Patient-Centered Clinical Decision Support Learning Network (PCCDS-LN). This 5-year effort (Grant #U18 HS024849), led by Dr. Barry Blumenfeld, brings together diverse stakeholders to promote a sustainable community around developing, disseminating, and applying evidence-enabled, patient-centered CDS. The goals of the PCCDS-LN are to: accelerate collaborative learning, identify barriers and facilitators to implementing PCOR findings into clinical practice with the assistance of CDS; recommend ways to implement PCOR findings as CDS; reinforce facilitators for effective CDS use; measure PCOR finding use in CDS; and evaluate its impact and plan for long-term sustainability. For more information on the PCCDS-LN, see: https://pccds-ln.org/.
- Electronic Data Methods (EDM) Forum: Second Phase (U18) (RFA-HS-13-004): This FOA supported one project to continue and expand the work of the Electronic Data Methods Forum (https://healthit.ahrq.gov/ahrq-funded-projects/past-health-it-initiatives/electronic-data-methods-edm-forum). This project ended in March 2017.

Other Health IT-Funded Grants. In addition to the grants described above, the Health IT Division funds grants with a health IT focus that are solicited through the following general Agency FOAs:

- Conference Grant Program Awards (R13) (PA-13-017): AHRQ supports conferences that help to further its mission to improve the quality, safety, efficiency, and effectiveness of healthcare for all Americans. Two health IT-focused conference grants were active during 2017.
- Career Awards (K01, K08): AHRQ funds Career Development (K01, K08) grants designed to support the next generation of health IT-focused researchers, including:
  - Mentored Clinical Scientist Research Career Development Award (K08) (PAR-09-085, PA-13-039). There were six K08 projects active in 2017.
  - Mentored Research Scientist Research Career Development Award (K01) (PAR-09-087). There were two K01 projects active in 2017.
- Patient-Centered Outcomes Research Pathway to Independence Award (K99/R00) (RFA-HS-13-002): The purpose of this funding is to increase and maintain a strong cohort of new and talented AHRQ-supported independent investigators trained in comparative effectiveness methods to conduct PCOR. One health IT-focused project was funded in 2013 and was ongoing at the end of 2017.
- Patient-Centered Outcomes Research Mentored Clinical Investigator Award (K08) (PA-13-180): This funding provides support for an intensive, mentored research career development experience in comparative effectiveness research methods as applied to PCOR. One health IT-focused grant was funded in 2016 and was ongoing at the end of 2017.
- Small Research Grant Program (R03) (PA-15-147): Supports different types of small research studies including: pilot and feasibility studies; secondary analysis of existing data; small, self-contained research projects; development of research methodology; and development of new research technology. Three health IT-focused research grants were funded through this PA; all were ongoing at the end of the year.
  Grant Highlight: Improving Adherence and Outcomes by Artificial I ntelligence-Adapted Text Messages (R21 HS022336) (https://healthit.ahrq.gov/ahrq-funded-projects/improving-adherence-and-outcomes-artificial-intelligence-adapted-text-messages)
  There are many well-known challenges related to medication management. A team of researchers led by Dr. Karen Farris used Reinforcement Learning (RL), an artificial intelligence method, to develop a model medication adherence system that automatically adapts text message communication to improve individual medication taking. Findings indicated that self-reported medication adherence significantly improved at 3 months in the intervention group compared to the control group. The distribution of text message themes changed over time indicating that the RL agent was learning and adapting.
- AHRQ Health Services Research Demonstration and Dissemination Grants (R18, PA-09-071, PA-13-046, PA-14-290). The AHRQ Health IT Division funds health IT demonstration and dissemination projects through an Agency-wide FOA. During 2017, there were a total of five active grants funded through these program announcements.
- AHRQ Health Services Research (R01): AHRQ funds projects through an Agency-wide FOA (PA-09-070, PA-13-045, PA-14-291) for ongoing extramural grants for research, demonstration, dissemination, and evaluation projects to support improvements in health outcomes, strengthen quality measurement and improvement, and identify strategies to improve access to care. There were 27 active health IT-focused grants funded through these FOAs during 2017.
- Centers for Education and Research on Therapeutics (CERTs) (U19, HS-11-004): AHRQ was given responsibility for administering the CERTs demonstration program authorized by Congress as part of the Food and Drug Administration Modernization Act of 1997 (Public Law 105-115). CERTs conduct research and provide education to advance the optimal use of drugs, medical devices, and biological products; increase awareness of the benefits and risks of therapeutics; and improve quality while cutting the costs of care. There was one health IT-focused U19 grant active in 2017, which ended in August 2017.
- Research Centers in Primary Care Practice-Based Research and Learning (P30) RFA (HS-12-002): P30 grants support Centers of Excellence in Primary Care Practice-Based Research and Learning that promote clinical, behavioral, and translational research activities. This FOA is intended for consortiums of three or more regional practice-based research networks (PBRNs), or national PBRNs with at least 120-member practices. There were two health IT-focused PBRN grants funded through this initiative in 2012; both ended during 2017.

### Contracts

A contract is an agreement that is initiated by the government to acquire a product or service under specified terms. The AHRQ Health IT Division supported one research contract that was active in 2017, with lifetime funding totaling $2.29 million.

- In 2016, AHRQ contracted with MITRE to generate a systematic and replicable process for transforming PCOR findings into shareable CDS standards and a publicly available CDS prototype (Contract #290-16-00001U, Patient-Centered Outcomes Research Clinical Decision Support Prototype Development and Dissemination). This project, called the “CDS Connect Project,” is focused on supporting the rapid translation of evidence-based PCOR into clinical practice through interoperable CDS “artifacts.” The term “artifacts” has been deliberately embraced by the CDS Connect project to provide the ability to support a variety of CDS that are not exclusively limited to the space of clinical alerts, including alerts, order sets, textual reports, citations, and so forth. CDS Connect is a web-based repository service that enables the CDS community to identify evidence-based standards of care, translate and codify information into an interoperable standard, and leverage tooling to promote a collaborative model of CDS development. For more information, please see https://cds.ahrq.gov/cdsconnect. Additional information on CDS Connect project activities in 2017 is included in Section III-A: Project Highlights.

### New Grant Funding Opportunities for 2018

In 2017, AHRQ announced several funding opportunities designed to fund basic health IT research and fill gaps in the field that will lead to improved design of health IT systems. Applicants are invited to submit proposals for research projects to be funded in 2018. They include:

- Developing New Clinical Decision Support to Disseminate and Implement Evidence-Based Research Findings (R18) (PA-17-261 (https://grants.nih.gov/grants/guide/pa-files/PA-17-261.html)): The purposes of this FOA are to develop new, reliable, valid, and usable CDS from evidence-based research findings and then demonstrate its effectiveness to improve care in clinical practice.
- Scaling Established Clinical Decision Support to Facilitate the Dissemination and Implementation of Evidence-Based Research Findings (R18) (PA-17-260 (https://grants.nih.gov/grants/guide/pa-files/PA-17-260.html)): This FOA will support research projects to extend (“scale”) the implementation and evaluation of well-established and effective CDS beyond the initial clinical setting or institution in which the CDS was originally developed and implemented, thereby extending the impact on clinical practice.
- Implementation and Evaluation of New Health IT Strategies for Collecting and Using Patient-Reported Outcome (PRO) Measures (U18) (PA-17-247 (https://grants.nih.gov/grants/guide/pa-files/PA-17-247.html)): This FOA will fund innovative collaborative investigations to understand how new health IT strategies can increase the utilization of PROs in ambulatory care settings and contribute to improved patient-centered health outcomes and quality of care.
- Utilizing Health Information Technology to Scale and Spread Successful Practice Models Using Patient-reported Outcomes (R18) (PA-17-077 (https://grants.nih.gov/grants/guide/pa-files/PA-17-077.html)): Projects funded through this FOA will support research that demonstrates how health IT can improve patient-centered health outcomes and quality of care in primary care and other ambulatory settings through the scale and spread of successful, health IT-enabled practice models that use PRO measures to achieve these objectives.
- Health Information Technology to Improve Health Care Quality and Outcomes (R21) (PA-17-246 (https://grants.nih.gov/grants/guide/pa-files/PA-17-246.html)): This FOA will support exploratory and developmental health IT projects that seek to apply data and evidence in innovative ways to facilitate population health management and patient-centered care delivery and coordination. These exploratory projects should be designed to develop health IT solutions that enable or facilitate population health management and patient-centered care delivery within healthcare organizations and health systems in a way that makes the solution shareable and configurable across different health domains and levels of scale.

## B Geographic Distribution of Projects

During 2017, projects were led by organizations located in 30 States plus the District of Columbia (see Figure 1). New York, with 18 projects, was the State with the highest number of active health IT projects, followed by Massachusetts with 16, and Illinois and Michigan each with 10. Projects are classified by the State where the lead organization is located, but many projects include collaborators from more than one organization in different States. For example, the Assess Risk of Wrong Patient Errors in an EMR That Allows Multiple Records Open project (Grant R21 HS023704), led by a principal investigator at Columbia University in New York, is conducting studies at two sites: Brigham and Women’s Hospital in Boston, Massachusetts, and at Montefiore Medical Center in the Bronx, New York.

Figure 1 Number of Projects Active in 2017 by State

This map of the U.S. shows the number of projects active in 2017 that are sponsored by AHRQ’s Health IT Division: - 0 project (20 states): AL, AR, DE, ID, FL, HI, KS, LA, ME, MS, MT, ND, NJ, NV, OK, RI, SD, VT, WV, WY - 1 project (8 states): AK, DC, IA, NE, NH, NM, TN, UT - 2 projects (4 states): GA, KY, MN, OR - 3-4 projects (7 states): AZ, CO, CT, MO, SC, TX, VA - 5+ projects (12 states): CA, IL, IN, MA, MD, MI, NC, NY, OH, PA, WA, WI Note: 151 projects in 30 states plus the District of Columbia

## C Characteristics of Health IT Projects

AHRQ funds diverse projects that focus on a range of health IT technologies, interventions, populations, medical conditions, settings, and type of care. Once a project is awarded, projects are reviewed and categorized using a detailed taxonomy. Projects may include one or more of any of these taxonomy categories.^1^

### Technologies

Projects are categorized by the health IT application or intervention being studied (Table 1) and can be tagged using more than one technology. The most common health IT category was EHRs/electronic medical records (EMRs) (n=45), followed by CDS (n=35), and mobile devices (n=26).

The Patient-Centered Virtual Multimedia Interactive Informed Consent (Grant #R21 HS023987) project is one example of a project categorized by more than one technology: consumer health informatics and mobile devices. This project, led by Dr. Fuad Abujarad, is enhancing the traditional patient informed consent process by developing the Patient-Centered Virtual Multimedia Interactive Informed Consent tool (VIC). The VIC will be developed as a patient-centered, web-based application with the ability to run on mobile devices.

Table 1 Technologies Studied

Technologies | Total
Electronic Health Record/Electronic Medical Record | 45
Clinical Decision Support System | 35
Mobile Device | 26
Consumer Health Informatics | 18
Patient Portal | 16
Mobile Phone | 11
Dashboard | 10
Patient-Generated Health Data | 10
Machine Learning | 9
Natural Language Processing System | 9
Telemedicine System | 7
Computerized Provider Order Entry System | 6
Health Information Exchange | 6
Virtual Reality | 6
Personal Health Record | 5
Text Messaging | 5
Clinical Documentation | 4
Remote Patient Monitoring | 4
Bioinformatics and Genomics | 3
Internet | 3
Registry | 3
Secure Messaging | 3
Voice Recognition | 3
Data Warehouse | 2
Social Media | 2
Architecture | 1
Clinical Informatics | 1
Clinical Messaging | 1
Data | 1
Electronic Prescribing | 1
Geographic Information System | 1
Informatics | 1
Kiosk | 1
Knowledge System | 1
Public Health Reporting System | 1
Radio Frequency Identification Device | 1
Radiology Information System | 1
Total | 263

### Medical Conditions Studied

The AHRQ Health IT Division funds projects that study the use of technology to improve management and outcomes of a variety of medical and health conditions, including cardiovascular disease, cancer, and substance abuse. Many of the projects evaluated the impact of an intervention on multiple health conditions or examined patients with co-morbid conditions.

For example, in the Treating Comorbid Depression During Care Transitions with Relational Agents project (Grant #R21 HS022938), led by Dr. Suzanne Mitchell, the team at Boston Medical Center developed the Sophie CBT System, an internet-accessed relational agent (RA), to deliver cognitive behavioral therapy for depression to patients with chronic illness and comorbid depression.

The most common medical conditions studied were unspecified chronic conditions (n=14), followed by mental and behavioral health (n=10), and diabetes (n=9). See Table 2 below.

Table 2 Medical Conditions Studied of Project Research

Medical Conditions | Total
Chronic Conditions | 14
Mental/Behavioral Health | 10
Diabetes Mellitus | 9
Cardiovascular Disease | 7
Cancer - Unspecified | 6
Hypertension | 6
Asthma | 5
Obesity | 5
Infectious Disease^*^ | 5
Gastrointestinal Disease | 4
Substance Abuse | 4
Breast Cancer | 3
Congestive Heart Failure (CHF) | 3
Coronary Artery Disease (CAD) | 3
Pregnancy | 3
HIV/AIDS | 2
Neurologic Disease | 2
Respiratory (Lung) Disease | 2
Stroke | 2
Tobacco Use | 2
Cerebral Palsy | 1
Cervical Cancer | 1
Colorectal Cancer | 1
Hyperlipidemia (HL) | 1
Prostate Cancer | 1
Renal (Kidney) Disease | 1
Sickle Cell Anemia | 1
Total | 104

* Infectious Disease includes viral, bacterial, and respiratory infection.

### Care Setting and Type of Care

Projects are categorized by the care setting (Table 3) and type of care (Table 4) of their research. For care setting, 42 projects active in 2017 were conducted in ambulatory settings. Thirty-one projects focused on inpatient care in hospitals, and 31 studies focused on care in patient homes.

Table 3 Care Setting of Project Research

Care Setting | Total
Ambulatory Setting | 42
Hospital^*^ | 31
Patient Home | 31
Academic Medical Center | 18
Emergency Department | 16
Federally Qualified Health Center | 6
Perioperative/Operative | 6
Intensive Care Unit | 5
Across the Healthcare System | 4
Community Health Center | 4
Outpatient | 4
Long-Term Care Facility | 3
Integrated Delivery Network | 2
Ambulatory Surgical Center | 1
Laboratory | 1
Pharmacy | 1
Rehabilitation Center | 1
Veterans Affairs Medical Center | 1
Total | 177

* Note: Hospital includes projects tagged as inpatient.

For type of care, 39 projects focused on primary care, followed by acute care (n=29), and specialty care (n=24). See Table 4.

The Comparison of Asynchronous Telepsychiatry Alongside Synchronous Telepsychiatry in Skilled Nursing Facilities project (Grant #R01 HS025395) is one example of a project categorized as both behavioral health and long-term care. This project, led by Dr. Glen Xiong, is evaluating the use of asynchronous telepsychiatry to provide mental health services to individuals living in skilled nursing facilities.

Table 4 Type of Care in Project Research

Type of Care | Total
Primary Care | 39
Acute Care | 29
Specialty Care | 24
Self-Management | 19
Pediatrics | 14
Surgery | 6
Ambulatory Care | 5
Long-Term Care | 4
Preventive Care | 4
Tertiary Care | 4
Behavioral Health | 3
Home Healthcare | 3
Orthopedics | 3
Family Medicine | 2
Obstetrics and Gynecology | 2
Multi-Specialty Care | 1
Urology | 1
Total | 163

### Healthcare Theme

Projects are categorized by healthcare theme (Table 5). Thirty-two projects active in 2017 were focused on patient-centered care. Twenty-six projects studied interventions to increase patient safety, and 21 projects focused on technology usability research.

The Sleep Promotion Toolkit for Hospitalized Patients project (Grant #R21 HS024330), awarded to Dr. Lichuan Ye, is one example of a project in the patient-centered care category. The project is revising a patient-centered sleep promotion toolkit called SLEEPkit and integrating it into an existing web-based patient portal.

Table 5 Healthcare Theme in Project Research

Healthcare Theme | Total
Patient-Centered Care | 32
Patient Safety | 26
Technology Usability | 21
Human Factors | 20
Patient Engagement | 20
Chronic Disease Management | 19
Patient-Reported Outcomes | 19
Mobile Health | 18
Quality Improvement | 17
Patient Education | 13
Transitions in Care | 13
Clinical Decisionmaking | 11
Care Coordination | 10
Preventive Medicine | 10
Sociotechnical Aspects | 10
Clinical Workflow | 8
Access to Care | 7
Medication Adherence | 7
Medication Errors | 7
Telehealth | 7
Care Planning | 6
Medication Safety | 6
Medication Management^*^ | 5
Quality Measurement | 5
Adverse Events | 4
Interoperability | 4
Medication Reconciliation | 3
Personalized Medicine | 3
Learning Health System | 2
Meaningful Use | 2
Smoking Cessation | 2
Health Literacy | 1
Total | 338

* Note: Includes projects tagged as medication or medication management.

### Populations Studied

The AHRQ Health IT Division funds projects that study various populations, some of which also overlap with AHRQ’s priority populations. AHRQ identifies “priority populations” as specified by Congress in the Healthcare Research and Quality Act of 1999 (Public Law 106-129), consisting of groups with unique healthcare needs or issues that require special focus, such as racial and ethnic minorities, low-income populations, and people with special healthcare needs.

Tables 6 through 10 outline the frequencies of projects categorized by each target population; projects can be tagged with more than one category. For example, in the School-Based Tele-Physiatry Assistance for Rehabilitative and Therapeutic Services for Children with Special Health Care Needs Living in Rural and Underserved Communities project (Grant #R01 HS025714), Dr. James Marcin and his team are studying the use of pediatric physiatrist medical direction using telemedicine with the goal to improve care for children with special healthcare needs who live in rural and medically underserved areas.

#### Age

The most common age category was adults (n=36), followed by children (n=23), and adolescents and young adults (n=15).

Table 6 Age Studied

Age Studied | Total
Adult | 36
Children | 23
Adolescent and Young Adult | 15
Elderly | 12
Infant | 3
Total | 89

#### Coverage Population

Four projects focused on those who were covered by Medicaid, while three other projects focused on individuals with private insurance, were Veterans, or who were uninsured (Table 7).

Table 7 Coverage Population Studied

Coverage Population Studied | Total
Medicaid | 4
Private Insurance | 1
Uninsured | 1
Veterans | 1
Total | 7

#### OMB Race and Ethnicity Populations

Eleven projects focused on specific Office of Management and Budget (OMB) race and ethnicity populations (Table 8).

Table 8 OMB Race and Ethnicity Studied

OMB Race and Ethnicity Studied | Total
Black or African American | 4
Hispanic or Latino | 3
American Indian or Alaska Native | 2
White | 2
Total | 11

#### Vulnerable Populations

The most frequent vulnerable populations studied in the projects were individuals with chronic care needs (n=17), followed by minority populations (n=12), medically underserved (n=10), and low-income populations (n=10).

Table 9 Vulnerable Population Studied

Vulnerable Population Studied | Total
Individuals with Chronic Care Needs | 17
Minority Populations | 12
Low Income Populations | 10
Medically Underserved Populations | 10
Inner City Populations | 6
Rural Populations | 6
Individuals with Disabilities | 2
Individuals with Low Literacy | 1
Individuals with Special Healthcare Needs | 1
Total | 65

#### Roles

The projects were also reviewed on the role of the population studied. The most common population roles were physicians (n=50), caregivers (n=21), and clinical staff (n=20).

Table 10 Role Studied

Role Studied | Total
Physician | 50
Caregiver | 21
Clinical Staff | 20
Nurse | 16
Researcher | 5
Surgeon | 4
Decision Maker | 3
IT Staff | 3
Physician Assistant | 3
Stakeholder | 3
Vendor | 3
Implementer | 2
Nurse Practitioner | 2
Payer | 2
Pharmacist | 2
Administrator | 1
C-Suite Officer | 1
Public Health Worker | 1
Total | 142

1 Project categories are up to date as of January 23, 2018. Projects categories may be updated when a project changes its approach and methodologies.