# I About the Health IT Division

The Agency for Healthcare Research and Quality (AHRQ) Health Information Technology (IT) Division’s mission is to produce and disseminate evidence about how health IT can make healthcare safer, higher quality, more accessible, equitable, and affordable, and to work within the U.S. Department of Health and Human Services and with other partners to make sure that the evidence is understood and used. Beginning in 2004, AHRQ has worked to fulfill this mission by investing in more than 600 research grants and contracts awarded to over 285 distinct institutions in 48 States and the District of Columbia.

AHRQ’s ongoing health IT activities aim to improve healthcare decision making, support patient-centered care, and improve the quality and safety of medication management. In recent years, AHRQ has expanded upon these initiatives to support health IT research on the use of technology by patients to improve the quality and effectiveness of care; safe and effective implementation of health technologies; dissemination and application of patient-centered outcomes research (PCOR) findings; and optimization of electronic health record (EHR) design to enhance usability and support clinical work flow.

In 2017, active projects focused on strengthening the understanding of healthcare providers’ information needs and decision making processes; consumers’ use of health IT to access and manage their health information; and strategies to effectively collect and use patient-reported outcomes data. See Section V for the full list of projects active during 2017.

Additionally, in 2017 AHRQ set forth several new funding opportunities that share the goal of improving the effectiveness of health IT systems. These new areas of research are directed at developing, scaling, and disseminating findings from new clinical decision support (CDS) tools as well as implementing, evaluating, and scaling ways to collect and utilize patient-reported outcome measures. In addition, a new FOA will support exploratory and developmental health IT projects that seek to apply data and evidence in innovative ways to facilitate population health management and patient-centered care delivery and coordination.

This report highlights the 151 projects funded by AHRQ’s Health IT Division that were active at any time during 2017. These projects span various areas of interest, funding mechanisms, and geographic distribution. Individual project profiles for all active and closed projects, project-related news, and publications are available on the AHRQ Health IT website at: www.healthit.ahrq.gov.